# Summary of Consensus Statements

Citation | Title | Notes | Category
Gray et al., 2014^1^ | Recommendations for EHR Use for Delivery of Adolescent Health Care | - Global, excluding China and India, EHR usage in 2010; - Adolescent confidentiality protection summarized; - Adolescent may forgo healthcare if their privacy is threatened.; - No incentive for EHR vendors, in current regulatory environment, to incorporate granular privacy controls in their products. | Privacy (Adolescents)
Patterson et al., 2013^2^ | Enhancing EHR Usability in Pediatric Patient Care: A Scenario-Based Approach | - Summary of the NIST 7865 report (see below) Highlights a few selected recommendations for EHR vendors and developers, small-group pediatric practices, and children's hospitals.; - Special considerations for pediatric patients from clinical experts; - Relevant concepts for human factors engineering from Human Factors experts | Pediatric-specific norms
Blythe et al., 2012^3^ | Standards for Health Information Technology to Ensure Adolescent Privacy | - Recommends nine basic principles for ‘ideal’ EHR; - Supports the caution that adolescent may forgo healthcare if privacy is threatened; - States that HIPAA not specific to adolescent privacy issues which may result in deferral to state laws regarding minors | Privacy (Adolescents)
Lowry et al., 2013^4^ | A Human Factors Guide to Enhance EHR Usability of Critical user Interactions when Supporting Pediatric Patient Care. [NIST.IR.7865] | - Highlights the user interactions unique to or salient for pediatric care and; - Details the unique features of pediatric patient care, in contrast to general adult patient care including patient physiology, complexity of routine tasks, and limited communication abilities.; - Provides conceptual model of unique user-related risks of EHR systems for pediatric patients.; - It covers human factors guidance for critical user interactions along 9 themes (patient identification, medications, alerts, growth chart, vaccinations, labs, newborn care, privacy, and radiology; - Suggests opportunities for innovations to consider for specialized child modules that can be used in conjunction with an established EHR.; - Appendix covers scenarios citing the potential pitfalls. | Pediatric-specific norms
ACOG Committee on Adolescent Health Care 2014^5^ | ACOG Committee Opinion # 599: Adolescent confidentiality and electronic health records | - Clarifies that HIPAA privacy rule leaves health care providers with questions about the relationship between HIPAA local applicable laws; - Standards lacking for state and other laws pertaining to minor consent, provisions for privacy and services governed by federal laws.; - Details the nature and requirement of the adolescent privacy and confidentiality of services consented by a minor | Privacy (Adolescents)
Gerstle et al., 2007^6^ | Electronic Prescribing Systems in Pediatrics: The Rationale and Functionality Requirements | - Describes the levels and implementation of e-prescribing.; - Cites pediatric specific advantages of CPOE; - Suggests and provides guidelines, potential barriers, and cautions against potential pitfalls.; - Cites benefits of e-prescribing to public health, patient, pharmacists, insurers and providers. | Medications / CPOE

## References

1 Gray SH, Pasternak RH, Gooding HC, et al. Recommendations for electronic health record use for delivery of adolescent health care. J Adolesc Health. Apr. 2014;54(4):487-90. [pmid: 24656534].
2 Patterson ES, Zhang J, Abbott P, et al. Enhancing electronic health record usability in pediatric patient care: a scenario-based approach. Jt Comm J Qual Patient Saf. Mar. 2013;39(3):129-35. [pmid: 23516763].
3 Blythe MJ, Del Beccaro MA. Standards for health information technology to ensure adolescent privacy. Pediatrics. Nov. 2012;130(5):987-90. [pmid: 23109684].
4 Lowry SZ, Quinn MT, Ramaiah M, et al. A human factors guide to enhance her usability of critical user interactions when supporting pediatric patient care. NISTIR 7865. US Department of Commerce: National Institute of Standards and Technology (NIST). 2013.
5 ACOG Committee on Adolescent Health Care. ACOG Committee Opinion no. 599: Adolescent confidentiality and electronic health records. Obstet Gynecol. May. 2014;123(5):1148-50. [pmid: 24785881].
6 Gerstle RS. Electronic prescribing systems in pediatrics: the rationale and functionality requirements. Pediatrics. Jun. 2007;119(6):1229-31. [pmid: 17545396].