# Key Informant Interviews

The Vanderbilt Evidence-based Practice Center (EPC) Director and the Agency for Healthcare and Quality (AHRQ) Task Order Officer reviewed the completed Disclosure of Interest forms for each Key Informant. We conducted discussion calls with nine Key Informants, one of whom was an employee of the Centers for Disease Control and Prevention. We were not required to obtain Office of Management and Budget (OMB) clearance for the Key Informant interviews because we included fewer than ten non-government associated participants.

We scheduled calls to include two or more Key Informants based upon availability and concordance of perspectives. The EPC Director and a co-investigator from the project team led each of the Key Informant discussion calls. We held three calls, each lasting 60 minutes. We recorded the discussion calls and distributed a summary to the participants. We organized the discussion summaries Guiding Question for analysis by the authors. The report authors identified key themes from multiple perspectives and noted unique perspectives from Key Informants.

Martha Bergren DNS, RN, NCSN, APHN-BC | Community Health Nursing Program | University of Illinois
Bobbie Byrne MD, MBA | Chief Information Officer | Edwards Health System
Mark A. Del Beccaro MD | Department of Pediatrics | University of Washington
Steve Downs MD, MS | Department of Pediatrics | Indiana University
Alex Fiks MD | Pediatric Research Consortium | Children's Hospital of Philadelphia
Chip Hart | Vendor | Physician's Computer Company
Hetty Khan MS, MGA, RN | Health Informatics | Centers for Disease Control and Prevention
Sue Kressly MD, FAAP | Physician | Kressly Pediatrics
Andrew Spooner MD, MS | Chief Medical Information Officer | Cincinnati Children's Hospital