# Literature Search Strategies

Medline via PubMed

Search terms | | Search results
#1 | (“pediatrics”[mh] OR “infant”[mh] OR “Child”[mh] OR “adolescent”[mh] OR “child health services”[mh] OR “intensive care units, pediatric”[mh] OR “hospitals, pediatric”[mh]) | 2850349
#2 | (child*[tiab] OR paediatr*[tiab] OR pediatr*[tiab] OR adolescent*[tiab] OR neonat*[tiab] OR infant*[tiab]) | 1535394
#3 | Search (#1) OR (#2) | 323347
#4 | (“Medical records systems, computerized”[mh] OR “decision support systems, clinical”[mh]) | 28598
#5 | ((“cpoe”[tiab] OR “computerized physician order entry”[tiab] OR “computerized order entry”[tiab] OR “computer order entry”[tiab] OR “cdss”[tiab] OR “clinical decision support systems”[tiab]) OR (electronic[tiab] AND (health record*[tiab] OR medical record*[tiab]))) | 13499
#6 | Search (#4) OR (#5) | 35200
#7 | Search (#3) AND (#6) | 3299
#8 | Limit to publication year >1998 | 3240

Abbreviations: mh=Medical Subject Heading; tiab=title/abstract word.

Notes:

a Using “medical order entry system” subject heading instead of “medical records systems, computerized” retrieves 2165 records. Using the broader term, “medical records systems, computerized” which encompasses “medical order entry system” and “electronic health records” retrieves an additional 1105 records- many of which may not be relevant to this topic. Cataloguers use the most specific heading available, however in this case, the broader term “medical records systems, computerized” was introduced in 1991, more than a decade before the more specific headings “medical order entry system” and “electronic health records”.

b Initial search conducted on 8/5/2014 retrieved 3038 records. On 1/5/2015, an updated search retrieved 202 additional unique records.

EMBASE

Search terms | | Search results
#1 | (pediatric* or child* or infant* or paediatric* or neonat* or adolescen*).mp | 3032578
#2 | (“computerized provider order entry” or “cpoe” or “electronic health” or “EHR” or “clinical decision support” or “CDS” or “CDSS”).mp | 18501
#3 | #1 AND #2 | 1475
#4 | Limits: NOT Medline, Publication Date: 1999-Current | 84

Notes:

a Search executed on 8/05/2014;

b After duplicates were removed, 75 unique records from were retained.