# Acknowledgments

The authors gratefully acknowledge R. Julian Irvine for project coordination and assistance with data abstraction; Dana Baker for research support; Rebecca Gray for editorial and other technical assistance; and Connie Schardt for help developing literature search strategies.

## EPC Program Director

- Stephanie Chang, M.D., MPH
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

## AHRQ Contact

- Elise Berliner, Ph.D.
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD