# Results

## Question 1 Heart Valves in Use and in Development

### Listing of Valves

Table 4 (conventional valves) and Table 5 (percutaneous valves) summarize the information we were able to compile, using the methods described above, on heart valves now in use or in development and their FDA status. In many instances, valve names used in the published literature were incomplete and did not precisely match device names provided by manufacturers or the FDA. In such cases, we attempted to match names based on other device characteristics, such as valve type, or from narrative descriptions in the literature. When matches could not be made with confidence, we listed all valve device names. Thus, Tables 4 and 5 may list some valves more than once using different names. Some of the valves listed are no longer manufactured, but may be encountered in patients with past valve replacements. These obsolete valves are also described in reviews and primary comparative studies. For these reasons, we included these valves in our summary tables.

Table 4 Conventional heart valves in use or in development

Company | Valve Name | Valve Position | Valve Type^*^ | FDA Indication?^†^ | Notes^‡^
Mechanical valves
Alliance Medical Technologies | Monostrut Cardiac Valve Prosthesis | Unknown | Tilting disc | Yes (FDA) | No longer marketed (FDA)
AorTech | Ultracor | Aortic | Tilting disc | Unable to determine
ATS Medical, Inc. | Bioflow | Unknown | Unknown | Unable to determine
ATS Medical, Inc. | Open Pivot Bileaflet Heart Valve | Mitral & aortic | Bileaflet | Yes (FDA)
Bjork-Shiley | Convex/Concave | Unknown | Tilting disc | Unable to determine
Bjork-Shiley | Low Profile | Unknown | Tilting disc | Unable to determine
Bjork-Shiley | Monostrut | Mitral & aortic | Tilting disc | Yes (non-FDA) | No longer marketed (non-FDA)
CarboMedics, Inc. | CarboMedics Prosthetic Heart Valve | Unknown | Bileaflet | Yes (FDA)
CarboMedics, Inc. | CarboMedics Valve | Mitral & aortic | Bileaflet | Yes (non-FDA) | FDA indicates that the CarboMedics Prosthetic Heart Valve has FDA indication, but does not specify which models.
CarboMedics, Inc. | Carbo-Seal Ascending | Aortic | Bileaflet | Yes (non-FDA) | FDA indicates that the CarboMedics Prosthetic Heart Valve has FDA indication, but does not specify which models.
CarboMedics, Inc. | Carbo-Seal Valsalva | Aortic | Bileaflet | Yes (non-FDA) | FDA indicates that the CarboMedics Prosthetic Heart Valve has FDA indication, but does not specify which models.
CarboMedics, Inc. | Optiform | Mitral | Bileaflet | Yes (non-FDA) | FDA indicates that the CarboMedics Prosthetic Heart Valve has FDA indication, but does not specify which models.
CarboMedics, Inc. | Orbis Universal | Mitral & aortic | Bileaflet | Yes (non-FDA) | FDA indicates that the CarboMedics Prosthetic Heart Valve has FDA indication, but does not specify which models.
CarboMedics, Inc. | Pediatric/Small Adult | Mitral & aortic | Bileaflet | Yes (non-FDA) | FDA indicates that the CarboMedics Prosthetic Heart Valve has FDA indication, but does not specify which models.
CarboMedics, Inc. | Reduced Series Aortic | Aortic | Bileaflet | Yes (non-FDA)
CarboMedics, Inc. | Standard Valve | Mitral & aortic | Bileaflet | Yes (non-FDA) | FDA indicates that the CarboMedics Prosthetic Heart Valve has FDA indication, but does not specify which models.
CarboMedics, Inc. | Top Hat Supra-Annular | Aortic | Bileaflet | Yes (non-FDA) | FDA indicates that the CarboMedics Prosthetic Heart Valve has FDA indication, but does not specify which models.
Direct Flow Medical, Inc. | Web site under construction— no information | Unknown | Unknown | Unable to determine
Edwards Lifesciences, LLC | Edwards Duromedics | Mitral & aortic | Bileaflet | Unable to determine | No longer marketed (non-FDA)
Edwards Lifesciences, LLC | Edwards MIRA Mechanical | Mitral & aortic | Bileaflet | Unable to determine
Edwards Lifesciences, LLC | Starr-Edwards Silastic Ball Heart Valve Prosthesis | Mitral | Caged-ball | Yes (FDA) | No longer marketed (non-FDA)
Edwards Lifesciences, LLC | Tekna | Unknown | Tilting disc | Unable to determine | No longer marketed (non-FDA)
Lillehei-Kaster | Lillehei-Kaster Heart Valve | Mitral & aortic | Tilting disc | Unable to determine | No longer marketed (non-FDA)
Lillehei-Kaster | Low Profile | Unknown | Tilting disc | Unable to determine | No longer marketed (non-FDA)
MedicalCV | Omnicarbon Cardiac Valve Prosthesis | Aortic | Tilting disc | Yes (FDA) | No longer marketed (FDA)
MedicalCV | Omniscience Cardiac Valve Prosthesis | Aortic | Tilting disc | Yes (FDA) | No longer marketed (FDA)
Medtronic, Inc. | Advantage Supra Bileaflet | Aortic | Bileaflet | Unable to determine
Medtronic, Inc. | Medtronic-Hall Prosthetic Mechanical Heart Valve | Mitral & aortic | Tilting disc | Yes (FDA)
On-X Life Technologies, Inc. | On-X Prosthetic Heart Valve | Aortic | Bileaflet | Yes (FDA)
Sorin Biomedica Cardio | Allcarbon | Mitral & aortic | Tilting disc | Unable to determine
Sorin Biomedica Cardio | Bicarbon Family | Mitral & aortic | Bileaflet | Unable to determine
Sorin Biomedica Cardio | Carbocast | Mitral | Tilting disc | Unable to determine
Sorin Biomedica Cardio | Monocast | Mitral & aortic | Tilting disc | Unable to determine
Sorin Biomedica Cardio | Monodisk | Mitral & aortic | Tilting disc | Unable to determine
Sorin Biomedica Cardio | Slimline | Aortic | Bileaflet | Unable to determine
St. Jude Medical | High Performance | Unknown | Unknown | Unable to determine
St. Jude Medical | St. Jude Medical Coated Aortic Valved Graft Prosthesis | Aortic | Bileaflet | Unable to determine
St. Jude Medical | St. Jude Medical Masters HP Valved Graft with Gelweave Valsalva Technology | Aortic | Bileaflet | Unable to determine
St. Jude Medical | St. Jude Medical Masters Mechanical Heart Valve with Silzone Coating | Mitral & aortic | Bileaflet | Unable to determine
St. Jude Medical | St. Jude Medical Masters Series Aortic Valved Graft | Aortic | Bileaflet | Unable to determine
St. Jude Medical | St. Jude Medical Masters Series Hemodynamic Plus Valve with FlexCuff Sewing Ring | Aortic | Bileaflet | Unable to determine | No longer marketed (non-FDA)
St. Jude Medical | St. Jude Medical Masters Series Mechanical Heart Valve | Mitral & aortic | Bileaflet | Unable to determine
St. Jude Medical | St. Jude Medical Masters Valved Graft with Hemashield Technology | Aortic | Bileaflet | Unable to determine
St. Jude Medical | St. Jude Medical Mechanical Heart Valve | Mitral & aortic | Bileaflet | Yes (FDA)
St. Jude Medical | St. Jude Medical Mechanical Valve Hemodynamic Plus Series | Mitral & aortic | Bileaflet | Unable to determine
St. Jude Medical | St. Jude Medical Regent Valve | Aortic | Bileaflet | Yes (non-FDA)
St. Jude Medical | St. Jude Medical Regent Valve with Silzone Coating | Aortic | Bileaflet | Unable to determine | No longer marketed (non-FDA)
Unknown | Debakey | Unknown | Unknown | Unable to determine
Unknown | Hall-Kaster | Unknown | Unknown | Unable to determine
Unknown | Harken | Unknown | Tilting disc | Unable to determine | No longer marketed (non-FDA)
Unknown | Smelloff-Cutter | Unknown | Unknown | Unable to determine
Bioprosthetic valves
ATS Medical, Inc. | ATS 3F Aortic Bioprosthesis, Model 1000 | Aortic | Equine | Yes (FDA)
Biocor | Biocor | Unknown | Porcine | Unable to determine | Stentless (non-FDA)
Bioflo | Unknown | Unknown | Bovine | Yes (non-FDA) | No longer marketed (non-FDA)
CarboMedics, Inc. | Mitroflow Aortic Pericardial Heart Valve | Aortic | Bovine | Yes (FDA)
Cryolife | O'Brien Model 300 | Aortic | Porcine | Unable to determine | Stentless (non-FDA)
Cryolife | SynerGraft Pulmonary Valve and Valved-Conduit Allograft | Pulmonary | Human | (Cleared, not approved) | Decellularized (non-FDA)
Edwards Lifesciences, LLC | Carpentier-Edwards Bioprosthesis | Aortic & mitral | Porcine | Yes (FDA)
Edwards Lifesciences, LLC | Carpentier-Edwards Duraflex Low Pressure Bioprosthesis | Mitral | Porcine | Yes (FDA)
Edwards Lifesciences, LLC | Carpentier-Edwards Perimount Magna Pericardial Bioprosthesis | Mitral & aortic | Bovine | Yes (non-FDA)
Edwards Lifesciences, LLC | Carpentier-Edwards Perimount Pericardial Bioprosthesis | Aortic & mitral | Bovine | Yes (FDA)
Edwards Lifesciences, LLC | Carpentier-Edwards Perimount Plus Pericardial Bioprosthesis | Mitral & aortic | Bovine | Yes (FDA) | Stented (non-FDA)
Edwards Lifesciences, LLC | Carpentier-Edwards Perimount RSR Pericardial Bioprosthesis | Aortic | Bovine | Yes (FDA)
Edwards Lifesciences, LLC | Carpentier-Edwards Perimount Theon | Mitral & aortic | Bovine | Unable to determine
Edwards Lifesciences, LLC | Carpentier-Edwards Supra- Annular Valve (SAV) Bioprosthesis | Mitral, aortic, & tricuspid | Porcine | Yes (FDA)
Edwards Lifesciences, LLC | Edwards Prima Plus Stentless Bioprosthesis | Aortic | Porcine | Yes (FDA)
Edwards Lifesciences, LLC | Prima Stentless Bioprosthesis (Subcoronary), Model 2500 | Aortic | Porcine | Yes (FDA) | No longer marketed (FDA)
Medtronic, Inc | Medtronic Contegra Pulmonary Valved Conduit (Models 200 and 200S) | Pulmonary | Bovine | Yes (FDA) | FDA approved for use as humanitarian use devices under HDEs (FDA).
Medtronic, Inc. | Freestyle Aortic Root Bioprosthesis | Aortic | Porcine | Yes (FDA) | Stentless (non-FDA)
Medtronic, Inc. | Intact | Aortic | Porcine | Unable to determine
Medtronic, Inc. | Medtronic Hancock I (Standard) Porcine Bioprosthesis | Mitral | Porcine | Yes (FDA)
Medtronic, Inc. | Medtronic Hancock II Bioprosthetic Heart Valve | Mitral & aortic | Porcine | Yes (FDA) | Stented (non-FDA)
Medtronic, Inc. | Medtronic Hancock Modified Orifice (MO) Porcine Bioprosthesis | Aortic | Porcine | Yes (FDA)
Medtronic, Inc. | Medtronic Mosaic Porcine Bioprosthesis | Mitral & aortic | Porcine | Yes (FDA) | Stented (non-FDA)
Shelhigh | Biomitral | Mitral | Porcine | Unable to determine
Shelhigh | Injectable Pulmonic Valve System | Apical approach pulmonic | Bovine | Unable to determine
Shelhigh | NR2000 Plus SemiStented | Aortic | Porcine | Unable to determine
Shelhigh | NR2000 Super Stentless | Aortic | Porcine | Unable to determine
Shelhigh | NR900A | Tricuspid | Porcine | Unable to determine
Shelhigh | Pulmonic Valve Conduit, No- React Treated, Model NR-4000 Series | Pulmonary | Bovine & porcine | Yes (FDA) | FDA approved for use as humanitarian use devices under HDEs (FDA).
Sorin Biomedica Cardio | Pericarbon Freedom Solo | Aortic | Bovine pericardium | Unable to determine
Sorin Biomedica Cardio | Pericarbon Freedom Stentless | Aortic | Bovine pericardium | Unable to determine
Sorin Biomedica Cardio | Pericarbon More | Aortic & mitral | Bovine pericardium | Unable to determine
Sorin Biomedica Cardio | Soprano | Aortic | Bovine pericardium | Unable to determine
St. Jude Medical | St. Jude Medical Biocor Porcine Stentless Bioprosthetic Heart Valve | Aortic | Porcine | Unable to determine
St. Jude Medical | St. Jude Medical Biocor Valve and Biocor Supra Valve | Mitral & aortic | Porcine | Yes (FDA)
St. Jude Medical | St. Jude Medical Epic Tissue Valve with Silzone Coating | Mitral & aortic | Porcine | Unable to determine | No longer marketed (non-FDA)
St. Jude Medical | St. Jude Medical Epic Valve and Epic Supra Valve | Aortic | Porcine | Yes (FDA) | Stented (non-FDA)
St. Jude Medical | St. Jude Medical Toronto SPV Valve (Stentless Porcine Aortic), Model SPA-101 | Aortic | Porcine | Yes (FDA)
Unknown | Ionescu-Shiley | Unknown | Bovine | Unable to determine | Stented (non-FDA)
Wessex Medical | Wessex | Unknown | Porcine | Unable to determine | Stented (non-FDA)

* Valve type for mechanical valves is either Caged-ball, Tilting disc, Bileaflet, or Unknown; and for bioprosthetic valves either Bovine, Equine, Porcine, Human, or Unknown.

† FDA indication column identifies the source of the FDA status as determined by the FDA (FDA) or a non-FDA source (non-FDA), or as Unable to determine.

‡ Notes column indicates the source of the note as determined by an FDA source (FDA) or a non-FDA source (non-FDA).

Abbreviations: FDA = U.S. Food and Drug Administration; HDE = humanitarian device exemptions.

Table 5 Percutaneous heart valves in use or in development

Company | Valve Name | Valve Position | Valve Type^*^ | FDA Indication?
CoreValve, Inc. | CoreValve ReValving System | Aortic | Porcine | No
Direct Flow Medical, Inc. | Direct Flow Medical Valve | Aortic | Equine | No
Edwards Lifesciences, LLC | Edwards SAPIEN, SAPIEN XT, Cribier Edwards & Percutaneous Heart Valve Technologies | Aortic | Equine | No
Medtronic, Inc. | Melody Valve | Aortic | Bovine | No
Sadra Medical | Lotus Valve | Aortic | Bovine | No
Unknown | Paniagua Heart Valve | Aortic | Unknown | No

* Valve type for percutaneous valves is either Bovine, Equine, Porcine, Human, or Unknown.

Abbreviation: FDA = U.S. Food and Drug Administration.

To date, no PHV has received FDA approval for the indication of aortic stenosis, but both the Edwards SAPIEN valve and the CoreValve ReValving System have received Conformité Européenne (European conformity, or CE) mark certification in Europe. The CE mark indicates that a medical device has met acceptable safety standards, but does not necessarily indicate that the device is efficacious.

### Classes of Heart Valves

Diseased heart valves can be replaced with mechanical or biological valves. Mechanical valves employ caged-ball, tilting disc, and bileaflet designs. The first artificial heart valve was a caged-ball design which utilized a metal cage to house a silicone coated ball.31 Tilting disc valves employ a disc controlled by a metal strut, which opens and closes with each cardiac cycle. Bileaflet valves utilize two semicircular leaflets that rotate around struts attached to the valve housing. At least six companies manufacture tilting disc or bileaflet mechanical valves that are currently available in the U.S. market (Table 4).

Biological valves (bioprosthesis or tissue valves) are classified into two major categories: xenografts made from bovine, porcine, or equine tissue; and homografts obtained from cadaveric donors. Xenografts may have a supporting frame (stent) or no supporting frame (stentless). Xenografts are much more readily available than homografts. We identified seven different manufacturers of FDA-indicated xenografts, including bovine, porcine, stented, and stentless models (Table 4).

Percutaneous heart valves are stent-based xenografts that are collapsed onto a catheter and are expanded at the time of implantation. Percutaneous valves are an emerging technology. We identified seven manufacturers of percutaneous valves (Table 5); none of these valves are FDA approved.

### Heart Valve Design

Replacement heart valves must be durable in order to minimize the risk of reoperation due to device failure. Factors that affect durability include: valve position; valve design; valve materials; and, for bioprostheses, the processes used to fix tissue and prevent calcification. A second goal is to replicate natural valve function as closely as possible. Desirable functional characteristics are: a non-thrombotic surface; materials that do not predispose to endocarditis; and favorable hemodynamic profiles, including laminar flow, small transvalvular gradients, and minimal regurgitant volumes. One measure of hemodynamic efficiency is captured by the effective orifice area (EOA); larger EOAs provide better flow.

### Theoretical Advantages and Disadvantages of Different Heart Valves

Mechanical heart valves are more durable than bioprostheses and are readily available. Mechanical valves have a simple and standard implantation technique. However, mechanical valves require lifelong anticoagulation because of a greater risk of thrombosis. Anticoagulation significantly increases the risk for bleeding that may require transfusion, and therefore requires careful monitoring. Because of shear forces, mechanical valves may also cause hemolytic anemia. Mechanical valves are hemodynamically inefficient in smaller sizes, a limitation for AVR in patients with a small aortic annulus. Caged-ball valves have the disadvantages of noise, hemodynamic inefficiency, and higher rates of thrombotic complications, necessitating a higher degree of anticoagulation than other mechanical valves.8 Edwards Lifesciences, LLC, discontinued production of the caged-ball valve in 2007. Caged-ball valves are no longer marketed in the United States and other developed countries. Tilting disc designs have superior hemodynamic efficiency to caged-ball designs, but have the disadvantage of severe hemodynamic compromise if disc thrombosis or immobility occurs. Bileaflet mechanical valves have greater EOA than tilting disc valves and may be less thrombogenic than other mechanical valves. Because mechanical valves have the longest durability, they are recommended for younger patients (< 65 years old) who are willing to take oral blood thinners (e.g., warfarin) and participate in anticoagulation monitoring.8

Bioprosthetic heart valves are also readily available and do not require chronic anticoagulation. In addition, they have a simple and standard implantation technique and may have fewer infectious complications than mechanical valves. However, bioprosthetic valves are less durable than mechanical valves. Structural deterioration is age-related, occurring more rapidly in younger age groups. Biological valves carry the theoretical risk of transmitting infection; at least one bovine valve has been recalled due to concern about transmission of bovine spongiform encephalopathy. Methods for tissue fixation and anticalcification have evolved since early bioprosthetic heart valves. Second-generation valves of this type are glutaraldehyde fixed under low pressure (compared with high pressure with the first generation), which is thought to increase durability. Stented bovine pericardial valves appear to have better hemodynamic performance and longer durability than stented porcine valves, especially in smaller sizes. Because stentless valves have less supporting material than stented bioprostheses, they have the potential for improved EOA and improved hemodynamic performance. Stentless valves may also be more durable than stented valves. However, stentless valves may be more technically difficult to implant, increasing operating room time and possibly surgical risk. Tissue-engineered valves using regeneration or repopulation approaches represent an emerging bioprosthetic technology; no such FDA-approved valves were identified.32 Regeneration involves the implantation of a restorable matrix that is expected to remodel in vivo and yield a functional valve composed of the cells and connective tissue of the patient. Repopulation involves implanting a porcine or human valve that has been depopulated of native cells, where the remaining scaffold of connective tissue is repopulated with the patient’s own cells. The theoretical advantage is a living tissue that responds to growth and physiological forces in the same way a native valve does. The 2006 ACC/AHA guidelines recommend a bioprosthesis for patients of any age who will not take or have major contraindications to warfarin therapy, for patients ≥ 65 years of age who do not have risk factors for thromboembolism, and for patients under age 65 who choose this approach for lifestyle reasons.8

The durability of homograft heart valves depends upon how the valve is recovered, processed, and preserved. Homograft aortic valves are supplied as a composite valve, aortic root, and part of the anterior mitral leaflet. This additional tissue is useful for severe disease due to endocarditis, and homografts are most frequently used for this indication. Durability of homografts does not appear to be superior to xenografts. Like xenografts, homograft (human) heart valves do not require chronic anticoagulation, risk of thromboembolism is very low, and these valves may be less likely to calcify than xenografts. Implantation procedures and reoperation for a failed valve are more complex than for standard mechanical or stented xenografts. The supply of homografts is much more limited than for mechanical valves or xenografts.

Because they are delivered via a catheter, percutaneous heart valves have the potential advantage of lower perioperative morbidity and mortality than valves implanted using conventional surgical approaches. There are six percutaneous approaches, one that uses direct apical heart puncture (the transapical approach), and five that involve cannulation of either the femoral vein, femoral artery, subclavian artery, axillary artery, or ascending aorta. None of these procedures requires cardiopulmonary bypass or a sternotomy, and the femoral and subclavian approaches may not require general anesthesia. The major theoretical advantages of the percutaneous approach are lower perioperative risk and less morbidity, leading to faster recovery times. Percutaneous valves have been used experimentally in patients deemed too high risk for conventional valve replacement surgery. Compared with valves implanted by open heart surgery, however, these valves are not sewn in, so there is an increased risk of migration. In addition, there are risks associated with cannulation, including thromboembolic events or perforation of major vessels. There is no long-term experience with percutaneous valves, so durability is uncertain and the implantation approach is evolving. Finally, percutaneous heart valves are not FDA approved, but the ongoing Placement of AoRTic TraNscathetER (PARTNER) trial is evaluating one of these valves in the United States.33

## Question 2 Studies Comparing Various Types of Conventional Heart Valves

### Scan of Systematic Reviews

Reviews identified. Our literature search identified 325 potentially relevant citations. Of these, 283 were excluded at the title-and-abstract screening stage, and 35 at the full-text screening stage. Seven publications, describing six distinct systematic reviews, addressed the comparative efficacy of various conventional prosthetic heart valves and met our other inclusion criteria.34–40 Major characteristics of these reviews are summarized in Table 6, and a detailed abstraction of each review is provided in Evidence Table 1 (Appendix B). Only one of the included reviews35 met all 10 of the quality assessment criteria we applied. Common limitations of other reviews included: inadequate or poorly described search strategies (5 of 6 reviews); failure to assess the quality of primary studies (5 of 6); and failure to examine for publication bias (4 of 6). Furthermore, observational studies and systematic reviews of observational studies are inherently limited in their ability to provide unbiased comparisons between different patient populations.

Table 6 Characteristics of included systematic reviews comparing various conventional heart valves

Review | Included Study Designs | Numbers of Studies and Subjects | Valve Comparison | Main Outcomes Reported
Kassai et al., 2000^34^ | RCT | 2 studies 1011 subjects | Aortic and/or mitral: Mechanical vs. bioprosthetic | Mortality, reoperation, bleeding
Kunadian et al., 2007^35^ | RCT | 11 studies 919 subjects | Aortic: Stented vs. non-stented bioprosthetic | Left ventricular mass regression, surgical procedure times
Lund and Bland, 2006^36^ | Observational | 38 studies 17,439 subjects | Aortic: Mechanical vs. bioprosthetic | Mortality
Puvimanasinghe et al., 2004^37^ and Puvimanasinghe et al., 2003^38^ | Observational | 22 studies 13,281 subjects | Aortic: St. Jude mechanical vs. porcine bioprosthetic | Life expectancy, thrombotic and bleeding complications
Puvimanasinghe et al., 2006^39^ | Observational | 13 studies 6481 subjects | Aortic: Carpentier-Edwards pericardial aortic vs. Carpentier-Edwards supra-annular bioprosthetic | Life expectancy, thrombotic and bleeding complications
Rizzoli et al., 2004^40^ | Observational | 11 studies 1160 subjects | Tricuspid: Bioprosthetic vs. mechanical valves | Survival, reoperation

Abbreviation: RCT = randomized controlled trial.

The included reviews are described in greater detail below, organized by valve comparison.

Mechanical vs. bioprosthetic valves. Four systematic reviews, described in five papers,34,36–38,40 compared mechanical and bioprosthetic valves. Kassai et al.34 identified two RCTs in adults (n = 1011) and one in children (n = 218) comparing mechanical with bioprosthetic valves in aortic or mitral valve position. Specific valves compared were the Bjork-Shiley or Lillehei-Kaster mechanical valves; and the Hancock, Carpentier-Edwards, or Angell-Shiley bioprosthetic valves. These valves are no longer in widespread use. Meta-analysis of the three trials showed no difference between mechanical and bioprosthetic valves for all-cause mortality at 5 years (relative risk [RR] 1.16, 95 percent confidence interval [CI] 0.97 to 1.39) or at 11 years (RR 0.94, 95 percent CI 0.84 to 1.06). Subjects receiving mechanical valves were less likely to undergo reoperation at 11 years (RR 0.4, 95 percent CI 0.29 to 0.58; x2 for heterogeneity, p = 0.059), and less likely to have endocarditis (RR 0.6, 95 percent CI 0.3 to 0.95; x2 for heterogeneity, p = 0.0001), but were more likely to have a bleeding complication (RR 1.65, 95 percent CI 1.26 to 2.18). A major limitation of this review is that the search only went through 1997.

A more recent systematic review36 also compared mechanical and bioprosthetic valves in the aortic position, limiting the literature to observational studies with at least 10 years of patient followup. The review identified 32 articles describing 38 case series and reporting outcomes in 17,439 patients. Studies with more than 10 percent obsolete valve types and studies that did not report mortality outcomes were excluded. Valves compared were the St. Jude bileaflet disc, CarboMedics, Sorin bileaflet and single disc, ATS, On-X, Edwards Mira, Edwards Duromedics, Tekna valve, or Medtronic-Hall tilting disc mechanical valves; and the Carpentier-Edwards Perimount pericardial, Carpentier-Edwards porcine standard, Carpentier-Edwards porcine supra-annular, Hancock II and MO porcine, Sorin Mitroflow pericardial, Medtronic Mosaic, Edwards Prima stentless, St. Jude x-cell, and Biocor porcine bioprosthetic valves. Statistical analysis using regression approaches showed no difference in mortality after adjusting for age, New York Heart Association class, and presence of aortic regurgitation (0.23 fewer deaths per 100 patient-years with bioprosthetic valves; 95 percent CI −0.99 to 0.63). The advantage of this review is that it focuses on studies describing experiences in clinical practice with currently used valves. However, an important limitation is the reliance on case series that do not directly compare mechanical with bioprosthetic valves. Indirect comparisons are more subject to bias and provide lower quality evidence.

Rizzoli et al.40 reviewed the outcomes for mechanical vs. bioprosthetic valves implanted in the tricuspid position. Eleven studies reporting “intra-institutional comparisons” of mechanical (n = 646) vs. biological (n = 514) valves were included. Specific study designs and valve types were not described, but a review of the primary literature cited showed these to be observational studies. Median duration of followup was 6.5 years. In seven studies reporting mortality, the hazard ratio was 1.07 (95 percent CI 0.84 to 1.35), indicating a small, statistically insignificant increase for mechanical vs. bioprosthetic valves. For three studies reporting freedom from reoperation, the pooled hazard ratio was 1.24 (95 percent CI 0.67 to 2.31) for mechanical vs. bioprosthetic valves. There are a number of limitations to this review, including: primary data from observational studies that are at increased risk for bias; lack of quality assessments for the primary data; and no evaluation for publication bias. Observational studies are at risk for confounding by indication, with particular valves being selected based on clinical indications, leading to important baseline imbalances in prognostic factors between the mechanical and bioprosthetic groups.

A 2004 review and microsimulation described in two publications compared selected bileaflet mechanical valves and stented porcine bioprosthesis in the aortic position.37,38 Specific mechanical valves considered were the St. Jude Medical bileaflet valves (standard and hemodynamic plus models); bioprosthetic valves were the Carpentier-Edwards standard and supra-annular valves, Hancock standard and modified orifice, and Hancock II valves. Studies in adult populations with predominately first-time AVR, valve events ascertained using standard definitions, and international normalized ratio values between 1.8 and 4.5 were included for review. Nine observational studies on St. Jude Medical valves and 13 studies on stented porcine bioprosthesis met inclusion criteria from the 144 identified in the search. Most of the 22 included studies were case series; 15 were retrospective designs, 5 were prospective, and 2 were not described. Meta-analysis showed the following event rates per 100 patient-years for mechanical vs. bioprosthetic valves: valve thrombosis (0.16 vs. 0.01); thromboembolism (1.6 vs. 1.3); hemorrhage (1.6 vs. 0.4); and endocarditis (3.9 vs. 3.2 in first 6 months). Incorporating these estimates into a microsimulation model for a 65-year-old man, life expectancy was projected at 10.4 years for mechanical vs. 10.7 years for bioprosthesis. Study limitations include the following: primary literature is predominately case series; lack of assessment for study quality; poorly described search strategy; and life expectancy results that depend on valid modeling.

In summary, two RCTs in adults showed no difference between mechanical and bioprosthetic valves in the aortic or mitral positions. However, the specific valves tested in these RCTs have been replaced by new models that may perform differently, and the study populations differ substantially from adults most commonly undergoing valve replacement today. In addition, standards for anticoagulation have changed to a lower international normalized ratio range, such that bleeding complications would now be expected to be lower. A large body of observational studies describing experiences with heart valve replacement has been summarized in systematic reviews. Although observational studies are at greater risk for bias than RCTs, and the systematic reviews evaluating them are of low to moderate quality, findings from those reviews are consistent with the findings from systematic reviews of RCTs.

Stented vs. stentless bioprosthetic valves. Left ventricular (LV) hypertrophy is a complication of aortic stenosis, and maximizing hemodynamic results from AVR is theorized to facilitate LV mass regression and improve clinical outcomes. Stentless valves are xenografts that have no additional structure (stent) allowing for larger valve sizes to be implanted, maximizing the EOA-to-tissue annulus ratio. Maximizing this ratio offers the potential for improved hemodynamic and clinical outcomes.

Only one systematic review evaluated stented vs. stentless bioprosthetic valves.35 This high-quality review included 11 RCTs of AVR conducted in Western Europe and Canada and reported between 1996 and 2006. A total of 445 subjects were randomized to stented valves: Carpentier Edwards Perimount, More, Mosaic, Intact, and Hancock II. The Prima Plus, Freedom, Freestyle and Toronto Stentless valves were implanted in 474 subjects. Six studies (n = 599) reported the primary outcome LV mass index at 6 months, and five studies (n = 550) reported this outcome at 12 months or later. LV mass index was lower for stentless valves at 6 months (weighted mean difference [WMD] −6.42, 95 percent CI −11.63 to −1.21), but this improvement disappeared after 12 months (WMD 1.19, 95 percent CI −4.15 to 6.53), and the meta-analysis showed significant heterogeneity that could not be explained by subgroup analyses. Secondary outcomes showed improved hemodynamic results for stentless valves (mean aortic gradient, WMD −3.57 mm Hg, 95 percent CI −4.36 to −2.78; peak aortic gradient, WMD −5.80, 95 percent CI −6.90 to −4.69), but longer operative cross-clamp time (WMD 23.5 minutes greater, 95 percent CI 20.4 to 26.1) and bypass time (WMD 29, 95 percent CI 24.4 to 34.0). There was no difference in mortality for stentless vs. stented valves at 1-year followup (odds ratio [OR] 0.91, 95 percent CI 0.52 to 1.57).

The primary limitations of this review are the short followup duration, the lack of symptom or functional status outcomes, and the significant unexplained heterogeneity across studies. These short-term studies suggest tradeoffs—improved hemodynamics at the expense of longer procedure times for stentless valves—and no evidence for improved cardiac function or lower mortality for stentless vs. stented valves at 12 months.

Comparisons of one bioprosthetic valve vs. another. A 2006 review and microsimulation39 compared two bioprosthetic valves, the Carpentier-Edwards pericardial valve and the Carpentier-Edwards supra-annular valve, both in the aortic position. These “second generation” valves were introduced in the 1980s and incorporated improvements in valve design aimed at reducing structural valvular deterioration and improving hemodynamic performance. The review included studies that focused on patients aged > 15 years with predominately first-time AVR. Additional inclusion criteria were: patients who predominately did not require long-term anticoagulation; valve sizes 19 to 31 mm; and valve events ascertained using standard definitions. Eight observational studies (n = 2685) on pericardial valves and five studies (n = 3796) on supra-annular valves met the inclusion criteria from the 48 identified in the search. Only two of these studies directly compared the two types of valves; the remaining 11 were case series of a single valve type. Meta-analysis of data from all included studies showed the following event rates per 100 patient-years for Carpentier-Edwards pericardial vs. Carpentier-Edwards supra-annular, respectively: valve thrombosis (0.03 vs. 0.02); thromboembolism (1.35 vs. 1.76); hemorrhage (0.43 vs. 0.46); endocarditis (0.62 vs. 0.39); and non-structural dysfunction (0.13 vs. 0.61). Neither CIs nor p-values were given for these comparisons. Incorporating these estimates into a microsimulation model for a 65-year-old man, life expectancy was projected at 10.8 years for the Carpentier-Edwards pericardial valve vs. 10.9 years for the Carpentier-Edwards supra-annular valve. This review and microsimulation are strengthened by model estimates from observational studies with long followup periods cited by the review authors. As in other reviews that rely on observational studies, indirect comparisons and confounding by indication may bias outcome estimates. In addition, the methods used in the review are poorly described, decreasing confidence in the estimates used in the microsimulation model in this particular instance.

### Scan of Randomized Controlled Trials

As described in the Methods section, in order to supplement the information obtained from systematic reviews, we sought to identify additional relevant RCTs and large observational studies that compared two or more conventional heart valves. For each such study we abstracted key design features to inform a judgment about the feasibility and possible value of conducting a systematic review of this literature.

Of the 416 potentially relevant articles identified by our search, 329 were excluded at the title-and-abstract screening stage, and 10 more at the full-text screening stage. Seventy-seven (77) articles, describing 57 unique RCTs involving 13,379 subjects, met our inclusion criteria (Appendix C, Table C1). Sixteen of these trials were included in the systematic reviews described immediately above. The 57 trials evaluated valve replacement in the aortic position (n = 43), aortic and mitral position (n = 11), or mitral position alone (n = 3). For the 43 studies exclusively evaluating AVR, the most common comparison was of bioprosthetic stented vs. bioprosthetic stentless valves (Table 7). For the 11 studies evaluating aortic and mitral valve replacement, comparisons were: homograft vs. mechanical (n = 1); one mechanical valve vs. another (n = 7); mechanical vs. bioprosthetic (n = 2); and one bioprosthetic valve vs. another (n = 1). The three studies of mitral valve replacement all compared mechanical valves.

Table 7 Types of valves compared in the aortic position randomized controlled trials^*^

| Homograft | Autograft | Mechanical | BP: Stented | BP: Stentless
Homograft | 0 | 3 | 0 | 1 | 3
Autograft | - | 0 | 1 | 0 | 0
Mechanical | - | - | 12 | 2 | 2
BP-stented | - | - | - | 7 | 15
BP-stentless | - | - | - | - | 1

* Number of studies is given for each comparison. The total number of comparisons exceeds the number of studies because some studies included more than one comparison.

Abbreviation: BP = bioprosthetic.

Within these major classes of valve types, the number of unique valves evaluated was large (Table 8). Valve technology has evolved, and some of these valves are no longer marketed in the United States. Some valves are designed for special purposes, such as a lower profile for a small annulus. A systematic review would need to carefully evaluate whether valves in a general class (e.g., mechanical) could be considered together for analytic purposes.

Table 8 Conventional valves evaluated in randomized controlled trials

Mechanical | Bioprosthetic: Stented | Bioprosthetic: Stentless
AorTech Ultracor | Carpentier-Edwards Pericardial | Carpentier Edwards Prima Plus
ATS Medical Bioflow | Carpentier-Edwards Perimount | Cryolife O‘Brien Model 300^*^
Bjork-Shiley Monostrut^*^ | Carpentier-Edwards Perimount | Medtronic Freestyle
Bjork-Shiley Low Profile^*^ | Magna | Sorin Freedom
Bjork-Shiley Convex/Concave^*^ | Medtronic Hall Hancock II | Biocor
CarboMedics (unspecified) | Medtronic Mosaic | St. Jude Toronto
CarboMedics Reduced bileaflet | Hancock standard^*^
Edwards Duromedics | Sorin More
Edwards Mira
Lillehei-Kaster^*^
Lillehei-Kaster Low Profile^*^
OnX
Medtronic Hall
Medtronic Advantage Supra
Sorin Slimline
St. Jude Hemodynamic Plus
St. Jude High Performance
St. Jude Regent
St. Jude Silzone^*^
Starr Edwards

* No longer commercially available.

Other critical issues affecting the feasibility of a systematic review are the timing, types, and quality of outcomes reported. Long-term studies are important to adequately evaluate mortality, reoperation for structural device failure, and long-term adverse effects such as stroke and bleeding complications. For the 42 studies of AVR, outcomes were reported at 1 year or sooner in 29 studies (69 percent), > 1 to 5 years in 10 studies (24 percent), and > 5 to 10 years in 3 studies (7 percent). Studies of aortic or mitral replacement generally had longer followup: > 1 to 5 years for 4 studies (36 percent); > 5 to 10 years for 5 studies (45 percent); and > 10 years for 2 studies (18 percent). Mean followup for the three mitral valve studies was about 5 years. The types of outcomes reported are summarized in Table 9. Intermediate outcomes such as hemodynamic changes were the most commonly reported. Although adverse effects were reported in about three-quarters of studies, we identified considerable heterogeneity in reporting, making a valid summary estimate more difficult.

Table 9 Number of randomized controlled trials reporting various outcomes

Outcomes | Aortic (n = 43) | Aortic/Mitral (n = 11) | Mitral (n = 3)
Mortality | 33 | 9 | 3
Clinical | 22 | 7 | 3
Hemodynamic | 39 | 2 | 2
Cardiac function | 36 | 1 | 1
Reoperation | 12 | 9 | 3
Adverse effects | 29 | 10 | 3

### Scan of Observational Studies

Of the 1160 potentially relevant citations identified by our search, 1096 were excluded at the title-and-abstract stage, and another 24 at the full-text stage. Forty (40) articles, each describing a unique study and involving a total of 332,551 subjects, met our inclusion criteria (see Appendix C, Table C-2). Twenty-six of these studies were included in the systematic reviews described above. A single Medicare claims study accounts for 307,054 of the subjects.41 Studies evaluated valve replacement in the aortic position (n = 22), aortic and/or other valve positions (n = 5), tricuspid position (n = 10), and mitral position (n = 2); 1 study did not report valve position. For the 27 studies evaluating aortic and/or other valve replacements, mechanical vs. bioprosthetic stented and bioprosthetic stented vs. bioprosthetic stentless were the most common comparisons, followed by comparisons of two bioprosthetic stented valves (Table 10). Of the 10 studies evaluating tricuspid valve replacement, nine compared mechanical with stented bioprosthesis.

Table 10 Types of valves compared in the aortic and/or other position^*^

| Homograft | Autograft | Mechanical | BP: Stented | BP: Stentless | BP: Mixed
Homograft | 0 | 0 | 0 | 2 | 0 | 0
Autograft | - | 0 | 0 | 0 | 0 | 0
Mechanical | - | - | 3 | 7 | 0 | 1
BP-stented | - | - | - | 5 | 7 | 0
BP-stentless | - | - | - | - | 1 | 0
BP-mixed | - | - | - | - | - | 0

* Number of studies is given for each comparison. Two studies that did not specify the type of bioprosthetic valve (stented vs. stentless) are omitted.41,117 The total number of comparisons exceeds the number of studies because some studies made more than one comparison.

Abbreviation: BP = bioprosthetic.

Thirty-six different named valves are evaluated in these studies, including 21 valves not evaluated in RCTs (Table 11).

Table 11 Conventional valves evaluated in observational studies

Mechanical | Bioprosthetic: Stented | Bioprosthetic: Stentless
AorTech Ultracor | Biocor porcine | Carpentier Edwards Prima
ATS Medical Bioflow | Carpentier-Edwards Perimount | Medtronic Freestyle
Bjork-Shiley Monostrut^*^ | Carpentier-Edwards porcine | Shelhigh Super stentless
CarboMedics (unspecified) | Hancock Standard^*^ | St. Jude Toronto
Debakey | Ionescu-Shiley bovine
Edwards Duromedics | Medtronic Intact
Edwards Tekna | Medtronic Mosaic
Hall-Kaster | Mitroflow
Harken | Sorin Pericarbon
OnX | Wessex Medical porcine
Medtronic Hall
Omniscience
Smelloff-Cutter
Sorin Allcarbon
Sorin Bicarbon
Sorin Carbocast
Sorin Monocast
Sorin Monodisc
St. Jude Medical
St. Jude High Performance
St. Jude Regent
Starr Edwards^*^

* No longer commercially available.

Compared with RCTs, observational studies are more likely to describe longer followup and report clinically important outcomes. Twenty-six of the 40 included studies (65 percent) had a mean followup duration exceeding 5 years. Most studies reported mortality rates, adverse effects, and reoperation rates (Table 12). A complicating issue for a possible systematic review is variability across studies in potential confounders controlled for in the analyses.

Table 12 Number of observational studies reporting various outcomes^*^

Outcomes | Aortic/Other (n = 27) | Tricuspid (n = 10) | Mitral (n = 2)
Mortality | 22 | 10 | 1
Clinical | 5 | 3 | 0
Hemodynamic | 9 | 0 | 0
Cardiac function | 9 | 0 | 0
Reoperation | 17 | 8 | 1
Adverse effects | 19 | 8 | 2

* One study that did not specify valve position is omitted.118

### Summary

Our literature scan identified six relevant systematic reviews, one of high quality, and a large body of RCTs and observational studies comparing different conventional heart valves with one another. The single high-quality meta-analysis evaluated 11 studies comparing stented with stentless bioprosthetic valves; we identified an additional four relevant trials and seven observational studies. There is sufficient literature to address other relevant comparisons, such as between mechanical and bioprosthetic valves, and between homografts and bioprosthetic valves, and to make selected within-class comparisons (e.g., among differing mechanical valves).

Based on varying duration of followup and types of outcomes reported, a systematic review would need to evaluate both RCTs and observational studies. RCTs of currently available valves tend to have shorter followup and thus are unable to evaluate critical outcomes such as reoperation for valve failure, late adverse effects, and long-term survival. Observational studies with longer-term followup can supplement findings from randomized trials. Systematic reviews will be complicated by heterogeneity in study design, valve position, and valve types. Other challenges include: whether to include studies of valves no longer marketed that may perform differently from modern valves; accounting for changes in anticoagulation targets and thus the risk for bleeding; and accounting for observational studies that vary by whether outcomes are adjusted for potential confounders. A systematic review that carefully develops a conceptual framework and evaluates the association between intermediate outcomes (such as hemodynamic changes) and long-term outcomes of importance to patients would be particularly useful.

## Question 3 Studies of Percutaneous Heart Valves

### Studies Identified

A total of 77 published reports were screened at the full-text stage; of these, 15 were excluded. The remaining 62 publications, describing 55 separate studies, assessed the feasibility and short-term safety of implanting percutaneous heart valves and met our other inclusion criteria.42–103

Important data from these studies, which represent 856 unique patients, are summarized in Tables 13 and 14; detailed abstractions of the included studies are provided in Evidence Table 2 (see Appendix B).

Table 13 Summary of published studies of percutaneous heart valve implantation

Study (including year of publication) | Valve name (as stated in report) | No. of patients (unique patients) | Followup (months) | Clinical indication | Successful implantation rate | Approach (no. of unique patients) | Catheter size | 30-day survival
Edwards Lifesciences, LLC
Cribier et al., 2004^44^ Eltchaninoff et al., 2002^43^ Cribier et al., 2002^42^ | Percutaneous Heart Valve | 6 1 (0) 1 (0) | 3 | Aortic stenosis | 5/6 (83%) | Femoral vein | 24 Fr | 3/6 (50%)
Bauer et al., 2004^45^ | Percutaneous Heart Valve | 8 | 1 | Aortic stenosis | 8/8 (100%) | Femoral vein (n = 6) Femoral artery (n = 2) | NR | 5/8 (63%)
Hanzel et al., 2005^46^ | Percutaneous Heart Valve | 1 | 5 days | Aortic stenosis | 1/1 (100%) | Aborted femoral vein to femoral artery | 24 Fr | NR
Cribier et al., 2006^47^ | Percutaneous Heart Valve | 36 (34)^a^ | 26 | Aortic stenosis | 27/36 (75%) | Femoral vein (n = 24) Femoral artery (n = 7) Aborted femoral artery to femoral vein (n = 1) Aborted procedures (n = 1) Death prior to procedure (n = 1) | NR | 21/36 (58%)
Chandavimol et al., 2006^48^ | Percutaneous Heart Valve | 1 | 12 | Aortic stenosis | 1/1 (100%) | Femoral artery | 24 Fr | 1/1 (100%)
Webb et al., 2007^49^ Webb et al., 2006^50^ Clavel et al., 2009^51^ Gutierrez et al., 2009^52^ | Cribier Edwards Cribier Cribier Edwards or Edwards SAPIEN Edwards-SAPIEN | 50 18 (0) 50 (0) 33 (0) | 12 12 1 | Aortic stenosis | 43/50 (86%) | Femoral artery | NR | 44/50 (88%)
Lichtenstein et al., 2006^53^ Ye et al., 2007^54^ | Cribier-Edwards Cribier-Edwards | 7 7 (0) | 6 | Aortic stenosis | 7/7 (100%) | Transapical | NA | 6/7 (86%)
Walther et al., 2008^55^ Walther et al., 2007^56^ | Edwards SAPIEN THV Cribier-Edwards | 59 30 (0)^b^ | 3 | Aortic stenosis | 55/59 (93%) | Transapical | NA | 51/59 (86%)
Walther et al., 2008^57^ | Edwards SAPIEN THV | 50 (20)^b^ | 18 | Aortic stenosis | 50/50 (100%) | Transapical | NA | 46/50 (92%)
Zierer et al., 2008^58^ | Edwards SAPIEN THV | 26 | 1 | Aortic stenosis | 25/26 (96%) | Transapical | NA | 22/26 (85%)
Svensson et al., 2008^59^ | Edwards | 40 | 11 | Aortic stenosis | 35/40 (88%) | Transapical | NA | 33/40 (83%)
Rodes-Cabau et al., 2008^60^ | Edwards- Sapien | 22 | > 6 | Aortic stenosis | 21/23 (91%) (2 procedures in 1 patient) | Femoral artery (n = 10) Transapical (n = 11) Aborted femoral artery to femoral vein (n = 1) | 24 Fr (n = 10) 22 Fr (n = 12) | 20/22 (91%)
Al-Attar et al., 2009^61^ | Edwards SAPIEN THV | 1 | 3 | Aortic stenosis | 1/1 (100%) | Transapical | NR | 1/1 (100%)
Clavel et al., 2009^62^ | Edwards SAPIEN | 1 | 0 | Aortic Stenosis | 1/2 (50%) (2 procedures in 1 patient) | Transapical | NR | 0/1 (0%)
Dvir et al., 2009^63^ | Edwards SAPIEN | 1 | 4 | Aortic Stenosis | 1/1 (100%) | Femoral artery | 24 Fr | 1/1 (100%)
Klaaborg et al., 2009^64^ | Edwards SAPIEN THV | 1 | 0 | Aortic Stenosis | 1/1 (100%) | Transapical | 26 Fr | NR
Moreno et al., 2009^65^ | Edwards SAPIEN | 1 | 0 | Aortic Stenosis | 1/1 (100%) | NR | NR | 0/1 (0%)
Wendt et al., 2009^66^ | Edwards SAPIEN | 1 | 1 | Aortic Stenosis | 1/1 (100%) | Transapical | NR | 1/1 (100%)
Wong et al., 2009^67^ | Edwards SAPIEN | 1 | 1 | Aortic Stenosis | 1/1 (100%) | NR | NR | 1/1 (100%)
Ye et al., 2009^68^ | Edwards SAPIEN | 1 | 16 | Aortic Stenosis | 1/2 (50%) (2 procedures in 1 patient) | Transapical | NR | 1/1 (100%)
Ng et al., 2009^69^ | Edwards- Sapien | 1 | 1 | Aortic Stenosis | 1/1 (100%) | Transapical | NR | 1/1 (100%)
Himbert et al., 2009^70^ | Edwards- SAPIEN | 75 | 10 | Aortic Stenosis | Femoral artery: 46/51 (90%) Transapical24/24 (100%) | Femoral artery (n = 51) Transapical (n = 24) | NR | Femoral artery: 47/51(92%) Transapical: 22/24 (92%)
Webb et al., 2009^71^ | SAPIEN SAPIEN XT | 22 3 | 1 | Aortic Stenosis | 25/25 (100%) | Femoral artery | 22/24 Fr | 25/25 (100%)
Chiam et al, 2009^72^ | Sapien THV | 1 | 1 | Aortic Stenosis | 1/1 (100%) | Femoral artery | 22 Fr | 1/1 (100%)
Dumonteil et al., 2009^73^ | Edwards Sapien | 1 | 1 | Aortic Stenosis | 1/1 (100%) | Femoral artery | NR | 1/1 (100%)
Bleiziffer et al., 2009^74^ NOTE: reports on both Edwards and CoreValve | Edwards- Sapien | 25 | 6 | Aortic Stenosis | NR by device | Femoral artery (n = 4) Transapical (n = 21) | 22/24 Fr NR | NR by device
Kolettis et al., 2009^75^ | 23 mm pericardial stented xenograft prosthesis | 1 | 0 | Aortic Stenosis | 1/1 (100%) | Transapical | NR | NR
Cheung et al., 2009^76^ | Cribier Edwards 9000MIS | 1 | 1 | Mitral stenosis | 1/1 (100%) | Transapical | 33 Fr | 1/1 (100%)
Totals: Edwards Lifesciences, LLC | | 584 (412) | | | 386/422^c^ (92%) | Femoral vein (n = 36) Femoral artery (n =153) Transapical (n = 216) Aborted femoral vein to femoral artery (n =1) Aborted femoral artery to femoral vein (n = 2) Aborted procedure (n = 1) Not reported (n = 2) Death prior to procedure (n = 1) | | 355/416^d^ (85%)
CoreValve ReValving System
Grube et al., 2005^77^ | CoreValve Revalving System | 1 | 0.5 | Aortic stenosis | 1/1 (100%) | Femoral artery | 25 Fr | NR
Grube et al., 2006^78^ | CoreValve Revalving System | 25 | 12 | Aortic stenosis | 22/25 (88%) | Femoral artery | 24 Fr (n = 10) 21 Fr (n = 15) | 20/25 (80%)
Grube et al., 2007^79^ | CoreValve Revalving System | 86 (76)^e^ | > 1 | Aortic stenosis | 76/86 (88%) | Femoral artery | 21 Fr (n = 50) 18 Fr (n = 36) | 76/86 (88%)
Grube et al., 2008^80^ | CoreValve Revalving System | 136 (122)^e^ | > 12 | Aortic stenosis | Generation 1: 7/10 (70%) Generation 2: 17/24 (71%) Generation 3: 93/102 (92%) | Femoral artery | 25 Fr (n = 10) 21 Fr (n = 24) 18 Fr (n = 102) | Generation 1: 6/10 (60%) Generation 2: 22/24 (92%) Generation 3: 91/102 (89%)
Marcheix et al., 2007^81^ | CoreValve Revalving System | 10 | 1 | Aortic stenosis | 10/10 (100%) | Femoral artery | 21 Fr | 7/10 (70%)
Berry et al., 2007^82^ Berry et al., 2007^83^ | CoreValve Revalving System | 13 1 (0) | 10 | Aortic stenosis | 11/13 (85%) | Femoral artery | 21 Fr | 11/13 (85%)
Lamarche et al., 2007^84^ | CoreValve Revalving System | 1 | 3 | Aortic stenosis | 1/1 (100%) | Femoral artery | 21 Fr | 1/1 (100%)
Lange et al., 2007^85^ | CoreValve Revalving System | 1 | 10 days | Aortic stenosis | 1/1 (100%) | Transapical | NA | NR
Wenaweser et al., 2007^86^ | CoreValve Revalving System | 1 | 12 | Aortic stenosis | 1/1 (100%) | Femoral artery | 21 Fr | 1/1 (100%)
Ruiz et al., 2008^87^ | CoreValve Revalving System | 1 | 12 | Aortic stenosis | 1/1 (100%) | Femoral artery | 25 Fr | 1/1(100%)
Bojara et al., 2009^88^ | CoreValve Revalving System | 1 | 1 | Aortic stenosis | 1/1 (100%) | Subclavian artery | 18 Fr | 1/1(100%)
Geist et al., 2009^89^ | CoreValve Revalving System | 1 | 3 | Aortic stenosis | 1/1 (100%) | NR | 18 Fr | 1/1(100%)
Piazza et al., 2009^90^ | CoreValve Revalving System | 5 | 10 | Aortic stenosis | 5/5 (100%) | Femoral artery (valve- in-valve) | NR | 4/5 (80%) NR for 1 pt
Piazza et al., 2009^91^ | CoreValve Revalving System | 3 | 3 | Aortic stenosis | 3/3 (100%) | Femoral artery | NR | 2/2 (100%) NR for 1 pt
Tamburino et al., 2009^92^ | CoreValve Revalving System | 30 | 1 | Aortic stenosis | 29/30 (97%) | Femoral artery | 18 Fr | 28/30 (93%)
Ussia et al., 2009^93^ | CoreValve Revalving System | 1 | 2 | Aortic stenosis | 1/1 (100%) | Femoral artery | 18 Fr | 1/1(100%)
Ussia et al., 2009^94^ | CoreValve Revalving System | 1 | 6 | Aortic stenosis | 1/2 (50%) (valve-in-valve after failed implantation) | Femoral artery | | 1/1(100%)
Bauernschmitt et al., 2009^95^ | CoreValve Revalving System | 1 | 0 | Aortic stenosis | 1/1 (100%) | Ascending aorta | NR | NR
Bollati et al., 2009^96^ | CoreValve Revalving System | 2 | 0 | Aortic stenosis | 2/2 (100%) | Ascending aorta | 18 Fr | NR
Asgar et al., 2009^97^ | CoreValve self-expanding nitinol prosthesis | 1 | 5 | Aortic stenosis | 1/1 (100%) | Axillary artery | 18 Fr | 1/1 (100%)
Bleiziffer et al., 2009^74^ NOTE: reports on both Edwards and CoreValve | CoreValve Revalving System | 127 | 6 | Aortic stenosis | NR by device | Femoral artery (n =117) Transapical (n = 5) Subclavian artery (n =3) Ascending aorta (n = 2) | 18 Fr | NR by device
Totals: CoreValve ReValving System | | 449 (424) | | | 286/323^f^ (89%) | Femoral artery (n =407) Transapical (n = 6) Subclavian artery (n =4) Ascending aorta (n =5) Axillary artery (n = 1) NR (n = 1) | | 275/315^g^ (87%)
Paniagua Heart Valve
Paniagua et al., 2005^98^ | Paniagua Heart Valve | 1 | 5 days | Aortic stenosis | 1/1 (100%) | Femoral artery | NR | 0/1 (0%)
Lotus Valve
Buellesfeld et al., 2008^99^ | Lotus Valve | 1 | 3 | Aortic stenosis | 1/1 (100%) | Femoral artery | 21 Fr | 1/1 (100%)
Melody Valve
Rodés-Cabau, et al., 2008^100^ | Melody valve | 1 | 3 | Pulmonary stenosis | 1/1 (100%) | Femoral vein | NR | 1/1 (100%)
Direct Flow Medical, Inc.
Schofer et al., 2008^101^ | Direct Flow Medical aortic valve | 15 | 1 | Aortic stenosis | 12/15 (80%) | Femoral artery | NR | 14/15 (93%)
Ventor Technologies
Falk et al., 2009^102^ | Ventor Embracer valve | 1 | 0.5 | Aortic stenosis | 1/1 (100%) | Transapical | 27 Fr | NR
Manufacturer not reported
Kapadia et al., 2009^103^ | NR | 1 | 18 | Aortic stenosis | 1/1 (100%) | Femoral artery | NR | 1/1 (100%)
Totals for all valves: | | 1053 (856) | | Aortic stenosis (n = 854) Pulmo- nary stenosis (n = 1) Mitral Stenosis (n = 1) | 839/917^h^ (92%) | Femoral vein (n = 37) Femoral artery (n =578) Transapical (n = 223) Subclavian artery (n =4) Ascending aorta (n =5) Axillary artery (n = 1) Other (n = 8) | | 781/903^i^ (86%)

a Data from two patients in this series are also reported in Cribier et al., 2004.^44^

b Walther et al., 2008;^55^ Walther et al., 2007;^56^ and Walther et al., 2008^57^ have overlapping patients (see Evidence Table 2 in Appendix B for details). These three studies combined report on 79 unique patients.

c Thirty-five (35) patients counted twice; 25 patients from Bleiziffer et al., 2009^74^ not included.

d Thirty-two (32) patients counted twice; survival not reported for 3 patients; 25 patients from Bleiziffer et al., 2009^74^ not included.

e Grube et al., 2006;^78^ Grube et al., 2007;^79^ and Grube et al., 2008^80^ have overlapping patients (see Evidence Table 2 in Appendix B for details). These three studies combined report on 223 unique patients.

f Twenty-six (26) patients counted twice; 127 patients from Bleiziffer et al., 2009^74^ not included.

g Twenty-four (24) patients counted twice; survival not reported for 6 patients; 127 patients from Bleiziffer et al., 2009^74^ not included.

h Fifty-six (56) patients counted twice; 5 patients with 2 procedures. Count includes 150/152 (99%) overall implantation success rate reported by Bleiziffer et al., 2009,^74^ which was not stratified by device manufacturer.

i Fifty-six (56) patients counted twice; survival not reported for 9 patients. Count includes 134/152 (88%) overall 30-day survival rate reported by Bleiziffer et al., 2009,^74^ which was not stratified by device manufacturer.

Abbreviations: Fr = French; n = number of patients; NA = not applicable; NR = not reported; pt = patient.

Table 14 Important variables in published studies of percutaneous heart valve implantation

Variable | Number of publications | Number of patients
Total numbers | 62 | 856
Position:
Aortic | 60 | 854
Pulmonic | 1 | 1
Mitral | 1 | 1
Valve manufacturers: *
Edwards Lifesciences | 35 | 412
CoreValve | 22 | 424
Endoluminal Technology Research | 1 | 1
Sadra Medical | 1 | 1
Medtronic | 1 | 1
Direct Flow Medical | 1 | 15
Ventor Technologies | 1 | 1
Manufacturer not reported | 1 | 1
Study type: **
Case reports | 35 | 37
Case series | 27 | 822
Approach: ***
Femoral vein | 5 | 37
Femoral artery | 32 | 578
Transapical | 17 | 223
Subclavian artery | 2 | 4
Ascending aorta | 2 | 5
Axillary artery | 1 | 1
Other | 7 | 8

* One publication included reports on both Edwards Lifesciences and CoreValve valves.

** One publication included case reports on 3 patients, and three case report publications included patients (n = 3) who were also described in case series; the latter are counted twice here.

*** Four publications reported on multiple approaches.

Our gray literature scan identified 12 scientific meeting abstracts that presented data on 11 studies not described in the published reports.104–115 These abstracts, which are summarized in Table 15, report data on 923 patients who underwent percutaneous heart valve replacement. Insufficient evidence was reported in the abstracts to make it possible to determine with confidence how many patients may be represented in more than one abstract, or in both an abstract and a fully published report.

Table 15 Summary of scientific meeting abstracts describing studies of percutaneous heart valve implantation

Valve Name | Meeting and Year | Abstract Reference | Sample Size | Date Last Patient Enrolled (actual or expected) | Clinical Indication | Approach | Country or Countries
Edwards SAPIEN
| TCT 2008 | Sack et al., 2008^104^ | 30 | NR | NR | Antegrade (n = 2) Retrograde (n = 28) | Germany
| TCT 2008 | Colombo et al., 2008^105^ | 29 | 5/08 | Aortic stenosis | Transfemoral (n = 23) or transapical (n = 6) | Italy, France
| AHA 2008 | Clavel et al., 2008^106^ | 50 | NR | Aortic stenosis | NR (“percutaneous”) | Canada
| AATS 2008 | Ye et al., 2008^107^ | 19 | 2006 | Aortic stenosis | Transapical | Canada
Subtotal: Edwards SAPIEN | | | 128
CoreValve ReValving System
| TCT 2008 | Behan et al., 2008^108^ | 12 | NR | Aortic stenosis | NR (“percutaneous”) | France
| TCT 2008 | Maier et al., 2008^109^ | 33 | 06/08 | Aortic stenosis | NR (“percutaneous”) | Netherlands
| TCT 2008 | Piazza et al., 2008^110^ | 646 | 04/08 | Aortic stenosis | NR (“transcatheter”) | Germany, Netherlands, France
| TCT 2008 | De Jaegere et al., 2008^111^ | 47 | 05/08 | Aortic stenosis | NR (“percutaneous”) | Netherlands
| ESC 2008 | Jilaihawi et al., 2008^112^ Jilaihawi et al., 2008^113^ | 30 | NR | Aortic stenosis | NR (“transfemoral”) | United Kingdom
Subtotal: CoreValve | | | 768
Unnamed
| TCT 2008 | Masson et al., 2008^114^ | 6 | NR | Failed mitral(n = 2) or aortic(n = 4) valve bioprosthesis | NR (“transcatheter”) | Netherlands
| AATS 2008 | Doss et al., 2008^115^ | 21 | NR | Aortic stenosis | Transapical (n = 21) vs. sternotomy (n = 30) | Germany
Subtotal: Unnamed | | | 27
Total | | | 923

Abbreviations: AATS = American Association of Thoracic Surgery; AHA = American Heart Association; ESC = European Society of Cardiology; n = number of patients; NR = not reported; TCT = Transcatheter Cardiovascular Therapeutics.

We identified four ongoing clinical trials via the ClinicalTrials.gov Web site (www.clinicaltrials.gov) (Table 16). Finally, the Scientific Information Packet provided by Edwards Lifesciences, LLC, included information on four relevant registries of percutaneous heart valve implantation (Table 17).

Table 16 Summary of ongoing studies of percutaneous heart valves

Valve Name | ClinicalTrials.gov Identifier | Sponsor | Name of Study | Anticipated Enrollment | Study Start Date | Condition Treated | Study Design | Country or Countries
Edwards SAPIEN | ClinicalTrials.gov ID: NCT00530894 | Edwards Lifesciences, LLC | PARTNER trial (Placement of AoRTic TraNscathetER valve trial) | 1040 | 4/07 | Critical aortic stenosis | Randomized clinical trial. 4 arms: Cohort A: Edwards SAPIEN THV valve vs. surgical valve Cohort B: Edwards SAPIEN THV vs. medical therapy | 23 centers in United States, Canada, Germany
Melody Transcatheter Pulmonary Valve | ClinicalTrials.gov ID: NCT00688571 | Medtronic Bakken Research Center | Melody Transcatheter Pulmonary Valve (TPV) Post- Marketing Surveillance Study | 60 | 10/07 | Heart valve disease | Non-randomized, open label, single group assignment treatment study | Germany
Edwards SAPIEN THV | ClinicalTrials.gov ID: NCT00676689 | Edwards Lifesciences, LLC | Pulmonic Feasibility Study of the SAPIEN Transcatheter Heart Valve (COMPASSION study) | 30 | 4/08 | Pulmonary valve insufficiency | Non-randomized, open label, single group assignment treatment study | United States
Ventor Embracer Heart Valve Prosthesis | ClinicalTrials.gov ID: NCT00677638 | Ventor Technologies | Catheter-Based Transapical Implantation of the Ventor Embracer Heart Valve Prosthesis in Patients with Severe Aortic Valve Disease | 30 | 6/08 | Aortic valve disease | Non-randomized, open label, single group assignment treatment study | Germany

Table 17 Summary of registries of percutaneous heart valve implantation^*^

Registries | Name of Study | Purpose | Anticipated Enrollment | Study Period | Condition Treated | Study Design | Country or Countries
Edwards SAPIEN THV | Registry of Endovascular Critical Aortic Stenosis Treatment (RECAST) trial (formerly I-REVIVE) registry | To demonstrate that the Edwards SAPIEN THV is a safe and effective treatment for elderly patients who are at a high risk, and therefore poor candidates for AVR surgery. | 106 | 1-year followup to be completed in January 2009 | NR | Edwards SAPIEN THV with retrograde transfemoral delivery system | France
Edwards SAPIEN THV | TRAVERCE (TRAnsapical Surgical DeliVERy of the Cribier- Edwards aortic bioprosthesis) | A first-in-man pilot study to evaluate the feasibility and safety of the transapical surgical delivery and implantation of the Edwards SAPIEN THV. | 172 | 12/04 to 4/08 | NR | | Germany, Austria
Edwards SAPIEN THV | SOURCE post- market registry | | 350 | NR | NR | Post-market registry | 30 European sites
Edwards SAPIEN THV^*^ | PARTNER EU trial (Placement of AoRTic TraNscathetER valve trial) | NR | 132 | NR | Severe aortic stenosis | Non-randomized, open label, multicenter single group assignment treatment study using either a transapical or transfemoral delivery approach | European sites

* Information provided by Edwards Lifesciences, LLC.

Abbreviations: AVR = aortic valve replacement; NR = not reported

### Results from Published Studies

Table 13, Table 14, and the paragraphs below summarize the most important findings from our scan of published studies. Data presented in abstract form at scientific meetings but not yet published in peer-reviewed journals are not included in this information synthesis for the following reasons: (1) meeting abstracts usually contain insufficient information to create sufficiently detailed evidence tables; (2) data presented at scientific meetings often differ from those that later appear in published reports, thereby putting into question the accuracy of the data presented in the abstracts; and (3) information presented at meetings is often derived from a subset of patients whose data have undergone only preliminary analysis. We describe the results from the abstracts we identified briefly in a separate section, below.

Number of studies and patients for each type of valve. We identified seven manufacturers of percutaneous heart valves through the published, peer-reviewed medical literature. The first published report of percutaneous valve replacement in an adult42 involved a valve that was initially manufactured by Percutaneous Heart Valve, Inc. The device is referred to as “Percutaneous Heart Valve” in the initial published studies. In 2004, Percutaneous Heart Valve, Inc., was acquired by Edwards Lifesciences, LLC. Subsequently, the same device was referred to as the Cribier-Edwards valve in published reports. More recent publications refer to that same device as the “Edwards SAPIEN Transcatheter Heart Valve” (or “SAPIEN THV”). Reports in the non-peer-reviewed literature describe the Ascendra Aortic Heart Valve Replacement System as the Cribier-Edwards valve for use in transapical, rather than transfemoral, delivery. The literature identified by our search strategy does not describe whether or how the differently named percutaneous heart valves acquired or manufactured by Edwards Lifesciences, LLC, have been modified over time. We identified 35 published reports, describing 28 studies, that reported results on a total of 412 unique patients who received a device manufactured by Edward Lifesciences, LLC, or Percutaneous Heart Valve, Inc.42–76

The second valve to appear in the published literature is the CoreValve ReValving System. The first generation was delivered via a femoral artery approach using a 25 French (Fr) catheter. The second generation of the valve was delivered via a 21 Fr catheter. The third and current generation is delivered via an 18 Fr catheter. We identified 22 reports, describing 21studies, that reported on a total of 424 unique patients who underwent percutaneous heart valve replacement with a CoreValve device.74,77–97

One report included in the above counts74 described two series of patients: one that received an Edwards Lifesciences valve (n = 25), and one that received a CoreValve valve (n = 127).

We identified a single published report for each of the five additional percutaneous heart valve manufacturers, plus one case report in which the names of the valve and manufacturer were not reported.103 A case report of the Paniagua Heart Valve, manufactured by Endoluminal Technology Research, was published in 2005.^98^ Case reports of the Lotus Valve (Sadra Medical)99 and the Melody Valve (Medtronic)100 were published in 2008. A case series that reported on the initial experience of the first 15 patients who received a Direct Flow Medical valve (Direct Flow Medical, Inc.) via using the femoral artery approach was also published in 2008.^101^ In 2009, a case report was published that involved the Ventor Embracer valve manufactured by Ventor Technologies.102

Type of studies. Thirty-five of the published reports were case reports, and 27 were case series, the latter representing a total of 822 patients. We did not identify any published RCTs. One study described the procedure and reported clinical outcomes on five patients who underwent a valve-in-valve procedure, whereby a CoreValve Revalving device was implanted within a previously implanted prosthetic heart valve in the aortic position.90 A single study compared clinical outcomes of 50 patients who underwent percutaneous heart valve (PHV) replacement at the aortic position with the Cribier-Edwards valve to historical controls comprised of 50 patients who underwent surgical valve replacement with a stented valve and 50 patients who underwent surgical valve replacement with a stentless valve.51 The controls were matched for sex, aortic annulus diameter, left ventricular ejection fraction, body surface area, and body mass index. Compared to the two surgically implanted valve groups, PHV replacement was associated with a lower transprosthetic gradient, more frequent aortic regurgitation, lower incidence of severe prosthesis-patient mismatch, and higher incidence of adverse reactions. Interpretation of these findings is complicated, however, by the many potential biases inherent to indirect comparisons between two or more patient populations whose clinical characteristics are significantly different between groups.

Variables associated with the procedure. Five reports described an antegrade approach via the femoral vein, 32 described a retrograde approach via the femoral artery, and 17 described a transapical approach, representing 37, 578, and 223 patients, respectively. Only 12 of the reports described the setting in which the procedure took place (e.g., operating suite, catheter lab), and only four described the training or specialty of the person performing the procedure. Successful implantation of a heart valve percutaneously was achieved in 92 percent of cases.

Size of studies and length of followup. All of the published reports were non-comparative case reports or series. The largest series involved 136 patients. All but seven included followup data 30 days after the procedure or until death of the patient. Eleven reports (18 percent) provided followup data 1 or more years after the procedure.

Patient population and concurrent and prior treatments. All of the studies included only adult patients. One reported on implantation of a prosthetic valve in the pulmonic position in a young adult with congenital heart disease,100 and one reported on implantation in the mitral valve position in an 80-year-old male with mitral stenosis.76 The remaining studies were conducted in patients with severe aortic stenosis who were considered to be at high surgical risk for conventional aortic replacement surgery (n = 854 patients). The mean age of patients was greater than 80 years. A small minority of patients had undergone heart valve replacement prior to undergoing percutaneous heart valve replacement. European System for Cardiac Operative Risk Evaluation (EuroSCORE) scores, which predict risk of death associated with open heart surgery, were reported in 15 of the 27 case series. Mean or median logistic EuroSCOREs among the patients represented in these 15 studies ranged from 11 to 41 percent, with 10 studies (67 percent) reporting a mean or median EuroSCORE greater than 23 percent.

Hemodynamic success rates. In nearly all patients, successful implantation of a prosthetic heart valve resulted in significant improvement in both valve area and either mean or peak pressure gradient across the replaced valve. Mild to moderate (Grade 1 or 2) paravalvular leaks were reported after the procedure in the majority of patients. LV ejection fraction was generally not significantly improved. In one series with matched comparison of PHV (n = 50) vs. biologic (n = 50) or mechanical (n = 50) SAVR, superior hemodynamics (transvalvular gradient and effective orifice area) were found for PHV vs. surgical procedures.51 Despite the limited PHV diameters available, the reported incidence of patient-prosthetic mismatch (insufficient effective orifice area for body surface area) is low.51

Clinical outcomes and harms reported. Thirty-day survival across all studies was 781/903 (86 percent), including 56 patients who were included in two published studies, and excluding patients for whom 30-day survival was not reported. We were unable to calculate a precise rate because there was some overlap of patients in a few of the published series, resulting in double counting of 56 patients (Table 13). This estimate remains unchanged after excluding studies with overlapping patients from the 30-day survival calculation. The most common causes of death attributed to the heart valve replacement procedure were myocardial infarction or stroke, arrhythmia, perforation of the vessels or heart wall, and heart failure.

The overall 30-day mortality rate of 14 percent is higher than rates reported for conventional aortic valve replacement (3 to 4 percent overall, with higher rates in patients over 65 in low-volume centers) but significantly lower than the operative mortality rate predicted by the logistic EuroSCORE for the patients in these published reports. Thirty-day outcomes were also reported as a composite endpoint of major adverse cardiovascular and cerebral events (defined as death from any cause, myocardial infarction, or stroke), with rates approximately eight percent in recent large series. Improvement in functional status, measured by the New York Heart Association (NYHA) classification, was reported in most of the series, with a reduction in severity from NYHA III–IV at baseline to I–II soon after PHV implantation. Among two PHV cohorts, 70–75% one-year survival rates have been reported,70,71 with approximately half of the deaths deemed non-cardiac in causation.

### Results from Scientific Meeting Abstracts

Table 15 briefly summarizes data from the 12 abstracts identified by our search of scientific meeting presentations. All of the eligible abstracts identified were presented in the year 2008; otherwise eligible abstracts presented in prior years were excluded because the studies they represented were subsequently published in full reports. The 12 abstracts represent 923 patients; despite our attempt to exclude studies that overlapped entirely with fully published reports, it is likely that some of the 923 patients represented in the abstracts listed in Table 15 are represented in the fully published reports summarized elsewhere in this report.

Four abstracts reported on a total of 128 patients who received the Edwards SAPIEN THV, and 6 abstracts reported the results of 5 case series involving 768 patients who underwent percutaneous heart valve replacement with the CoreValve ReValving System. An additional 2 studies involving 27 patients did not report the name of the device, but circumstantial evidence suggests that the Edwards SAPIEN THV was used in both of these studies.

One of the studies presented as an abstract compared a transapical approach (n = 21) with sternotomy (n = 30) in a series of 51 consecutive patients.115 This study is one of only two studies we identified in our searches of the published and gray literature that involved a direct, albeit non-randomized, comparison. Three abstracts specified that they used a transapical approach, and six used the term “percutaneous” or “transcatheter” without specifying which specific approach was used. None of the studies represented by the meeting abstracts were conducted in the United States; all were conducted in Europe.

### Ongoing Clinical Trials

We identified four pertinent ongoing trials on the ClinicalTrials.gov website (www.clinicaltrials.gov) (Table 16). Three of these are non-randomized, open-label, single group assignment treatment studies involving three different valves: the Melody Transcatheter Pulmonary Valve, Edwards SAPIEN THV, and Ventor Embracer Heart Valve. Pulmonary valve insufficiency is the clinical indication for the former, whereas the latter two are enrolling patients with either “heart valve disease” or “aortic valve disease.”

The fourth ongoing trial represents the first RCT of percutaneous heart valves. The Placement of AoRtic TraNscathetER valve trial, or PARTNER Trial, is sponsored by Edwards Lifesciences, LLC. According to the listing in ClinicalTrials.gov, “the purpose of this study is to determine the safety and effectiveness of the device and delivery systems (transfemoral and transapical) in high-risk, symptomatic patients with severe aortic stenosis.”33

The start date of the PARTNER Trial was in April 2007. Estimated study completion date is September 2014. Anticipated enrollment is 1040. Eligible patients with aortic stenosis who are at high surgical risk (defined as operative mortality of ≥ 15 percent and/or Society of Thoracic Surgeons risk score ≥ 10) will be randomly allocated to receive the Edwards SAPIEN THV percutaneously or undergo conventional surgical valve replacements. Eligible patients who are not candidates for conventional surgical valve replacement (defined as operative mortality or serious, irreversible morbidity ≥ 50 percent) will be randomly llocated to the Edwards SAPIEN THV or medical management (or balloon aortic valvuloplasty, as indicated).

### Registries

Our systematic search of the published literature and our extensive search of the gray literature did not identify any ongoing or recently-closed-but-as-yet-unpublished registries of percutaneous heart valves. Information about the four registries summarized in Table 17 was provided by Edwards Lifesciencs, LLC. These four registries include patients with the Edwards SAPIEN THV in up to 30 sites in Europe. None appears to include patients in the United States.

## Question 4 Variables that May Affect Outcomes for Percutaneous Heart Valves

The evidence derived from the 62 fully published reports identified by our search strategy that pertains to the 6 categories of variables identified above is summarized in the sections that follow. Because we did not identify any published reports that included primary data from human studies of percutaneous mitral valve replacement, this section of the report focuses exclusively on percutaneous AVR.

### Prosthesis Characteristics

Five of the seven companies identified as percutaneous heart valve manufacturers are each represented by a single report in the published literature. Four of these are case reports,98–100,102 and one is a case series involving 15 patients;101 none of the five reports included a direct comparator. This is insufficient evidence to comment on potential relationships between the design or manufacturer of a valve and clinical outcomes for these devices.

In contrast, we identified 35 reports representing 412 patients and 22 reports representing 424 patients for the Edwards SAPIEN THV and the CoreValve ReValving System, respectively. Implantation success and 30-day survival were 92 percent and 85 percent, respectively, for the Edwards SAPIEN THV (including its precursors, the Percutaneous Heart Valve and the Cribier-Edwards valve), and 89 percent and 87 percent, respectively, for the CoreValve ReValving System. These data do not support definitive conclusions regarding the possible superiority of one of these devices over the other. All of the included studies were either case reports or case series.

Given the absence of an experimental design or direct control group, comparisons across studies are limited by numerous confounding factors, including patient and operator characteristics, clinical indication for the procedure, treatment setting, and secular trends. The inability to distinguish between causative and confounding factors applies to all of the variables considered here that may theoretically impact clinical outcomes associated with percutaneous heart valve replacement.

Larger catheter sizes may limit patient eligibility due to insufficient iliac artery size; they are also associated with greater risk of vascular trauma to iliac or aortic arteries. The potential relationship between decreasing catheter size and improved clinical outcomes is illustrated by the study by Grube et al.,80 which demonstrated an implantation survival rate of 92 percent and a 30-day survival rate of 89 percent with the smaller, third-generation of the CoreValve system compared with rates of 70 percent and 60 percent, respectively, with the larger, first-generation delivery system. It is possible, however, that the improved outcomes observed over time in the series of patients reported in this study are due to factors independent of the smaller catheter size, such as operator experience with the procedure or other variables that may have changed over time.

Although clearly important for approaches that involve cannulation of major vessels, the size of the delivery system catheter is theoretically less important for the transapical approach. There is also a theoretical advantage of devices that permit either post-deployment adjustment or intraoperative deployment of a second percutaneously delivered heart valve within a malpositioned prosthetic valve. The reports we reviewed were not designed to address either of these issues.

### Implantation Approach

Six delivery or access approaches have been reported for percutaneous AVR: femoral vein, femoral artery, subclavian artery, axillary artery, ascending aorta, and directly through the wall of the left ventricle (transapical). The femoral vein approach offers the theoretical advantage of femoral venous rather than arterial access, potentially reducing complications related to injury to arterial vessels. In this approach, a catheter is introduced through the groin into the femoral vein, and then maneuvered to the right atrium and across the intra-atrial septum and mitral valve to reach the aortic valve. This approach carries the risk of residual atrial septal defect from the large delivery catheter required, as well as the risk of procedure-associated mitral regurgitation. In addition, the complexity of this technique prevented widespread adoption of the procedure, particularly with first-generation devices.

In current practice, the femoral vein approach has largely been replaced by the femoral artery approach, which allows a simpler route of delivery. In this approach, a catheter is introduced through the groin into the femoral and iliac arteries to the aorta and then to the aortic valve. Limitations of this approach include the large diameter of the delivery catheter that must be accommodated by the iliac artery, and the tortuosity and atherosclerosis of the aorta in many patients who have aortic stenosis. The femoral vein, femoral artery, subclavian artery, axillary artery, and ascending aorta approaches all have risks associated with vessel cannulation, including vessel wall injury, and in the case of retrograde (i.e., arterial) approaches, thromboembolic complications related to traversing the aorta with a catheter.

Transapical AVR is a recently developed option for patients with unfavorable aortic or iliac artery anatomy for the transfemoral approach, and is performed by cardiac surgeons via a left thoracotomy incision. Compared with transfemoral approaches, transapical valve replacement has theoretical advantages associated with the straight-line approach to the aortic valve, including potentially reducing complications of aortic atheroembolic events, bleeding at the site of vascular access, and mitral valve damage. However, this technique carries the potential risks associated with surgical access and general anesthesia. Reported implantation success and 30-day survival rates are 89 percent and 89 percent, respectively, for the femoral artery approach, and 94 percent and 87 percent, respectively, for the transapical approach.

### Treatment Setting

Percutaneous heart valve replacements have generally been performed in cardiac catheterization laboratory settings because of the availability of appropriate devices and fluoroscopic imaging equipment for the procedural aspects. To date, the majority of percutaneous valve implantations have occurred under general anesthesia, with the subsequent requirement that the catheterization laboratories used must allow for anesthesia equipment and personnel. Because the procedure involves implantation of a prosthetic device, the maintenance of a sterile setting is important to reduce the risk of infection.

The advent of percutaneous AVR via a transapical approach emphasizes the overlap between cardiac catheterization laboratory and operating suite settings for these procedures. This overlap has led to the development of “hybrid” catheterization laboratories developed and equipped to perform procedures traditionally done in operating suites. In addition to standard catheterization imaging equipment, these hybrid settings may involve ceiling-supported lighting equipment to provide higher lighting output, and heating, ventilation, and air conditioning systems to provide laminar flow diffusion of air typically found in operating suites.

Too few published reports identified by our literature reviewed reported sufficient detail about the treatment setting to determine whether this variable impacts outcomes associated with percutaneous valve replacement.

### Operator Characteristics

The intersection of procedural elements described above may stimulate increased collaboration between cardiologists (including both interventional cardiologists and echocardiographers), cardiothoracic surgeons, and cardiac anesthesiologists. Although interventional cardiologists by training have greater experience with percutaneous transfemoral procedures and devices, cardiac surgeons are experienced with techniques necessary for transapical valve replacement, as well as possible repair for vascular access complications and cardiopulmonary bypass and ventricular support. Cross-specialty training may develop, with incorporation of simulation technology for endovascular training.

Too few published reports identified by our literature review reported sufficient detail about operator characteristics to determine whether this variable impacts outcomes associated with percutaneous valve replacement; however, some authors reported improved outcomes with increased operator experience with a given percutaneous heart valve replacement procedure.59,80

### Type of Anesthesia

A theoretical advantage of approaches that involve cannulation of a vessel compared with either a transapical approach for percutaneous heart valve replacement or conventional aortic valve surgery is that the former can be administered using conscious sedation, as opposed to general anesthesia. The literature we reviewed did not provide sufficient evidence to comment on the independent risk contribution of general anesthesia vs. conscious sedation as they apply to percutaneous heart valve replacement.

### Patient Characteristics

A patient’s clinical status, coexisting medical conditions, and corresponding operative risk are all variables that significantly impact clinical outcomes for any surgical procedure.116 With the sole exceptions of a 21-year-old woman with congenital heart disease with a pulmonic valve prosthesis,100 and an 80 year-old man with mitral stenosis,76 all of the patients in the published reports identified by our systematic literature search had symptomatic aortic stenosis with a correspondingly relatively high predicted operative mortality for conventional AVR by cardiac surgery with cardiopulmonary bypass, as measured by validated surgical risk models (either the logistic EuroSCORE or the Society of Thoracic Surgeons Predicted Risk of Mortality. The amount and quality of the published data, and the way the data are reported, render it difficult to identify any specific patient characteristics related to outcomes associated with PHV replacement. However, in case series, it is notable that actual 30-day mortality rates with PHV replacement were substantially lower than the expected perioperative mortality rates with major surgery, as predicted by the EuroSCORE.

The reports identified by our literature search did not provide sufficient evidence to determine which patient characteristics impact outcomes associated with percutaneous valve replacement. Factors associated with mortality in conventional valve surgery may be applicable to percutaneous valve replacement. These factors include age, functional status, cardiac factors, and medical comorbidity.7,13–15