# References Cited in the Technical Brief

1 Singh JP, Evans JC, Levy D, et al. Prevalence and clinical determinants of mitral, tricuspid, and aortic regurgitation (the Framingham Heart Study). Am J Cardiol. 1999;83(6):897-902. [pmid: 10190406].
2 Lindroos M, Kupari M, Heikkila J, et al. Prevalence of aortic valve abnormalities in the elderly: an echocardiographic study of a random population sample. J Am Coll Cardiol. 1993;21(5):1220-1225. [pmid: 8459080].
3 Shapira OM, Kelleher RM, Zelingher J, et al. Prognosis and quality of life after valve surgery in patients older than 75 years. Chest. 1997;112(4):885-894. [pmid: 9377949].
4 Olsson M, Granstrom L, Lindblom D, et al. Aortic valve replacement in octogenarians with aortic stenosis: a case-control study. J Am Coll Cardiol. 1992;20(7):1512-1516. [pmid: 1452924].
5 Olsson M, Janfjall H, Orth-Gomer K, et al. Quality of life in octogenarians after valve replacement due to aortic stenosis. A prospective comparison with younger patients. Eur Heart J. 1996;17(4):583-589. [pmid: 8733092].
6 Walther T, Chu MWA, Mohr FW. Transcatheter aortic valve implantation: time to expand?. Current Opinion in Cardiology. 2008;23(2):111-116. [pmid: 18303522].
7 Ambler G, Omar RZ, Royston P, et al. Generic, simple risk stratification model for heart valve surgery. Circulation. 2005;112(2):224-231. [pmid: 15998680].
8 Bonow RO, Carabello BA, Kanu C, et al. ACC/AHA 2006 guidelines for the management of patients with valvular heart disease: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (writing committee to revise the 1998 Guidelines for the Management of Patients With Valvular Heart Disease): developed in collaboration with the Society of Cardiovascular Anesthesiologists: endorsed by the Society for Cardiovascular Angiography and Interventions and the Society of Thoracic Surgeons [erratum appears in Circulation. 2007 Apr 17;115(15):e409]. Circulation. 2006;114(5):e84-e231. [pmid: 16880336].
9 Schwarz F, Baumann P, Manthey J, et al. The effect of aortic valve replacement on survival. Circulation. 1982;66(5):1105-1110. [pmid: 7127696].
10 Turina J, Hess O, Sepulcri F, et al. Spontaneous course of aortic valve disease. European Heart Journal. 1987;8(5):471-483. [pmid: 3609042].
11 Horstkotte D, Loogen F. The natural history of aortic valve stenosis. European Heart Journal. 1988;9(Suppl E):57-64. [pmid: 3042404].
12 Iivanainen AM, Lindroos M, Tilvis R, et al. Natural history of aortic valve stenosis of varying severity in the elderly. American Journal of Cardiology. 1996;78(1):97-101. [pmid: 8712130].
13 Nashef SA, Roques F, Michel P, et al. European system for cardiac operative risk evaluation (EuroSCORE). European Journal of Cardio-Thoracic Surgery. 1999;16(1):9-13. [pmid: 10456395].
14 Nashef SAM, Roques F, Hammill BG, et al. Validation of European System for Cardiac Operative Risk Evaluation (EuroSCORE) in North American cardiac surgery. European Journal of Cardio-Thoracic Surgery. 2002;22(1):101-105. [pmid: 12103381].
15 Shroyer ALW, Coombs LP, Peterson ED, et al. The Society of Thoracic Surgeons: 30-day operative mortality and morbidity risk models. Annals of Thoracic Surgery. 2003;75(6):1856-1864. discussion 1864–1865. [pmid: 12822628].
16 Bouma BJ, van der Meulen JH, van den Brink RB, et al. Variability in treatment advice for elderly patients with aortic stenosis: a nationwide survey in The Netherlands. Heart. 2001;85(2):196-201. [pmid: 11156672].
17 Casserly IP, Kapadia SR. Advances in percutaneous valvular intervention. Expert Review of Cardiovascular Therapy. 2005;3(1):143-158. [pmid: 15723583].
18 Iung B, Baron G, Butchart EG, et al. A prospective survey of patients with valvular heart disease in Europe: The Euro Heart Survey on Valvular Heart Disease. European Heart Journal. 2003;24(13):1231-1243. [pmid: 12831818].
19 Jebara VA, Dervanian P, Acar C, et al. Mitral valve repair using Carpentier techniques in patients more than 70 years old. Early and late results. Circulation. 1992;86:II53-59. [pmid: 1424034].
20 Hendren WG, Nemec JJ, Lytle BW, et al. Mitral valve repair for ischemic mitral insufficiency. Annals of Thoracic Surgery. 1991;52(6):1246-1251. discussion 1251–1252. [pmid: 1755677].
21 Lee EM, Porter JN, Shapiro LM, et al. Mitral valve surgery in the elderly. Journal of Heart Valve Disease. 1997;6(1):22-31. [pmid: 9044072].
22 Marinopoulos S, Dorman T, Ratanawongsa N, et al. Effectiveness of Continuing Medical Education. Evidence Report/Technology Assessment No. 149 (Prepared by the Johns Hopkins Evidence-based Practice Center, under Contract No. 290-02-0018.) AHRQ Publication No. 07-E006. Rockville, MD. Agency for Healthcare Research and Quality. January. 2007. Available at: http://www.ahrq.gov/downloads/pub/aevidence/pdf/cme.pdf.
23 Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of reporting of meta-analyses. Lancet. 1999;354(9193):1896-1900. [pmid: 10584742].
24 Canadian Coordinating Office for Health Technology Assessment. Percutaneous heart valve replacement. 2005;(28).
25 Walther T, Mohr FW. Aortic valve surgery: time to be open-minded and to rethink. European Journal of Cardio-Thoracic Surgery. 2007;31(1):4-6. [pmid: 17113304].
26 Carroll JD. The evolving treatment of aortic stenosis: do new procedures provide new treatment options for the highest-risk patients?. Circulation. 2006;114(6):533-535. [pmid: 16894048].
27 Fish RD. Percutaneous heart valve replacement: enthusiasm tempered. Circulation. 2004;110(14):1876-1878. [pmid: 15466655].
28 Cohn WE. Percutaneous valve interventions: where we are and where we are headed. American Heart Hospital Journal. 2006;4(3):186-191. [pmid: 16894254].
29 Leon MB, Kodali S, Williams M, et al. Transcatheter aortic valve replacement in patients with critical aortic stenosis: rationale, device descriptions, early clinical experiences, and perspectives. Seminars in Thoracic & Cardiovascular Surgery. 2006;18(2):165-174. [pmid: 17157238].
30 Piazza N, de Jaegere P, Schultz C, et al. Anatomy of the aortic valve complex and its implications for transcatheter implantation of the aortic valve. Circulation: Cardiovascular Interventions. 2008;1:74-81. [pmid: 20031657].
31 Matthews AM. The development of the Starr-Edwards heart valve. Texas Heart Institute Journal. 1998;25(4):282-293. [pmid: 9885105].
32 National Horizon Scanning Centre - The University of Birmingham. Tissue engineered heart valves. Horizon Scanning Review, July 2002. National Horizon Scanning Centre, Department of Public Health and Epidemiology, University of Birmingham. Birmingham, UK. Available at: www.publichealth.bham.uk/horizon.
33 ClinicalTrials.gov record on the Placement of AoRTic TraNscathetER Valve Trial (PARTNER trial). ClinicalTrials.gov identifier: NCT00530894. Available at: http://www.clinicaltrials.gov/ct2/show/NCT00530894?term=aortic+transcatheter&rank=1. Accessed January 13, 2010.
34 Kassai B, Gueyffier F, Cucherat M, et al. Comparison of bioprosthesis and mechanical valves, a meta-analysis of randomised clinical trials [erratum appears in Cardiovasc Surg 2001 Jun;9(3):304–306]. Cardiovascular Surgery. 2000;8(6):477-483. [pmid: 10996104].
35 Kunadian B, Vijayalakshmi K, Thornley AR, et al. Meta-analysis of valve hemodynamics and left ventricular mass regression for stentless versus stented aortic valves. Annals of Thoracic Surgery. 2007;84(1):73-78. [pmid: 17588387].
36 Lund O, Bland M. Risk-corrected impact of mechanical versus bioprosthetic valves on long-term mortality after aortic valve replacement. Journal of Thoracic & Cardiovascular Surgery. 2006;132(1):20-26. [pmid: 16798297].
37 Puvimanasinghe JPA, Takkenberg JJM, Edwards MB, et al. Comparison of outcomes after aortic valve replacement with a mechanical valve or a bioprosthesis using microsimulation. Heart. 2004;90(10):1172-1178. [pmid: 15367517].
38 Puvimanasinghe JPA, Takkenberg JJM, Eijkemans MJC, et al. Choice of a mechanical valve or a bioprosthesis for AVR: does CABG matter? European Journal of Cardio-. Thoracic Surgery. 2003;23(5):688-695. discussion 695.
39 Puvimanasinghe JPA, Takkenberg JJM, Eijkemans MJC, et al. Comparison of Carpentier-Edwards pericardial and supraannular bioprostheses in aortic valve replacement. European Journal of Cardio-Thoracic Surgery. 2006;29(3):374-379. [pmid: 16386920].
40 Rizzoli G, Vendramin I, Nesseris G, et al. Biological or mechanical prostheses in tricuspid position? A meta-analysis of intra-institutional results. Annals of Thoracic Surgery. 2004;77(5):1607-1614. [pmid: 15111151].
41 Schelbert EB, Vaughan-Sarrazin MS, Welke KF, et al. Valve type and long-term outcomes after aortic valve replacement in older patients. Heart. 2008;94(9):1181-1188. [pmid: 18070945].
42 Cribier A, Eltchaninoff H, Bash A, et al. Percutaneous transcatheter implantation of an aortic valve prosthesis for calcific aortic stenosis: first human case description. Circulation. 2002;106(24):3006-3008. [pmid: 12473543].
43 Eltchaninoff H, Tron C, Cribier A. Percutaneous implantation of aortic valve prosthesis in patients with calcific aortic stenosis: technical aspects. Journal of Interventional Cardiology. 2003;16(6):515-521. [pmid: 14632949].
44 Cribier A, Eltchaninoff H, Tron C, et al. Early experience with percutaneous transcatheter implantation of heart valve prosthesis for the treatment of end-stage inoperable patients with calcific aortic stenosis. Journal of the American College of Cardiology. 2004;43(4):698-703. [pmid: 14975485].
45 Bauer F, Eltchaninoff H, Tron C, et al. Acute improvement in global and regional left ventricular systolic function after percutaneous heart valve implantation in patients with symptomatic aortic stenosis [erratum appears in Circulation. 2005 Jan 25;111(3):378]. Circulation. 2004;110(11):1473-1476. [pmid: 15226213].
46 Hanzel GS, Harrity PJ, Schreiber TL, et al. Retrograde percutaneous aortic valve implantation for critical aortic stenosis. Catheterization & Cardiovascular Interventions. 2005;64(3):322-326. [pmid: 15736245].
47 Cribier A, Eltchaninoff H, Tron C, et al. Treatment of calcific aortic stenosis with the percutaneous heart valve: mid-term follow-up from the initial feasibility studies: the French experience. Journal of the American College of Cardiology. 2006;47(6):1214-1223. [pmid: 16545654].
48 Chandavimol M, McClure SJ, Carere RG, et al. Percutaneous aortic valve implantation: a case report. Canadian Journal of Cardiology. 2006;22(13):1159-1161. [pmid: 17102835].
49 Webb JG, Pasupati S, Humphries K, et al. Percutaneous transarterial aortic valve replacement in selected high-risk patients with aortic stenosis. Circulation. 2007;116(7):755-763. [pmid: 17646579].
50 Webb JG, Chandavimol M, Thompson CR, et al. Percutaneous aortic valve implantation retrograde from the femoral artery. Circulation. 2006;113(6):842-850. [pmid: 16461813].
51 Clavel MA, Webb JG, Pibarot P, et al. Comparison of the hemodynamic performance of percutaneous and surgical bioprostheses for the treatment of severe aortic stenosis. Journal of the American College of Cardiology. 2009;53(20):1883-1891. [pmid: 19442889].
52 Gutierrez M, Rodes-Cabau J, Bagur R, et al. Electrocardiographic changes and clinical outcomes after transapical aortic valve implantation. American Heart Journal. 2009;158(2):302-308. [pmid: 19619709].
53 Lichtenstein SV, Cheung A, Ye J, et al. Transapical transcatheter aortic valve implantation in humans: initial clinical experience. Circulation. 2006;114(6):591-596. [pmid: 16880325].
54 Ye J, Cheung A, Lichtenstein SV, et al. Six-month outcome of transapical transcatheter aortic valve implantation in the initial seven patients. European Journal of Cardio-Thoracic Surgery. 2007;31(1):16-21. [pmid: 17126558].
55 Walther T, Simon P, Dewey T, et al. Transapical minimally invasive aortic valve implantation: multicenter experience. Circulation. 2007;116(11 Suppl):I240-I245. [pmid: 17846311].
56 Walther T, Falk V, Borger MA, et al. Minimally invasive transapical beating heart aortic valve implantation proof of concept. European Journal of Cardio-Thoracic Surgery. 2007;31(1):9-15. [pmid: 17097302].
57 Walther T, Falk V, Kempfert J, et al. Transapical minimally invasive aortic valve implantation; the initial 50 patients. European Journal of Cardio-Thoracic Surgery. 2008;33(6):983-988. [pmid: 18294859].
58 Zierer A, Wimmer-Greinecker G, Martens S, et al. The transapical approach for aortic valve implantation. Journal of Thoracic & Cardiovascular Surgery. 2008;136(4):948-953. [pmid: 18954635].
59 Svensson LG, Dewey T, Kapadia S, et al. United States feasibility study of transcatheter insertion of a stented aortic valve by the left ventricular apex. Annals of Thoracic Surgery. 2008;86(1):46-54. discussion 54–55. [pmid: 18573397].
60 Rodés-Cabau J, Dumont E, De LaRochellière R, et al. Feasibility and initial results of percutaneous aortic valve implantation including selection of the transfemoral or transapical approach in patients with severe aortic stenosis. American Journal of Cardiology. 2008;102(9):1240-1246. [pmid: 18940300].
61 Al-Attar N, Raffoul R, Himbert D, et al. False aneurysm after transapical aortic valve implantation. Journal of Thoracic & Cardiovascular Surgery. 2009;137(1):e21-e22. [pmid: 19154869].
62 Clavel MA, Dumont E, Pibarot P, et al. Severe valvular regurgitation and late prosthesis embolization after percutaneous aortic valve implantation. Annals of Thoracic Surgery. 2009;87(2):618-621. [pmid: 19161796].
63 Dvir D, Assali A, Vaknin H, et al. Percutaneous aortic valve implantation: early clinical experience and future perspectives. Isr Med Assoc J. 2009;11(4):244-249. [pmid: 19603600].
64 Klaaborg KE, Egeblad H, Jakobsen CJ, et al. Transapical transcatheter treatment of a stenosed aortic valve bioprosthesis using the Edwards SAPIEN Transcatheter Heart Valve. Annals of Thoracic Surgery. 2009;87(6):1943-1946. [pmid: 19463633].
65 Moreno R, Dobarro D, Lopez de Sa E, et al. Cause of complete atrioventricular block after percutaneous aortic valve implantation: insights from a necropsy study. Circulation. 2009;120(5):e29-e30. [pmid: 19652115].
66 Wendt D, Eggebrecht H, Kahlert P, et al. Successful transapical aortic valve implantation four weeks before 97th birthday. Interactive Cardiovascular & Thoracic Surgery. 2009;8(6):684-686. [pmid: 19286680].
67 Wong DR, Boone RH, Thompson CR, et al. Mitral valve injury late after transcatheter aortic valve implantation. Journal of Thoracic & Cardiovascular Surgery. 2009;137(6):1547-1549. [pmid: 19464478].
68 Ye J, Webb JG, Cheung A, et al. Transcatheter valve-in-valve aortic valve implantation: 16-month follow-up. Annals of Thoracic Surgery. 2009;88(4):1322-4. [pmid: 19766829].
69 Ng AC, van der Kley F, Delgado V, et al. Percutaneous valve-in-valve procedure for severe paravalvular regurgitation in aortic bioprosthesis. JACC Cardiovasc Imaging. 2009;2(4):522-523. [pmid: 19580737].
70 Himbert D, Descoutures F, Al-Attar N, et al. Results of transfemoral or transapical aortic valve implantation following a uniform assessment in high-risk patients with aortic stenosis. Journal of the American College of Cardiology. 2009;54(4):303-311. [pmid: 19608027].
71 Webb JG, Altwegg L, Masson JB, et al. A new transcatheter aortic valve and percutaneous valve delivery system. Journal of the American College of Cardiology. 2009;53(20):1855-1858. [pmid: 19442884].
72 Chiam PTL, Koh TH, Chao VTT, et al. Percutaneous transcatheter aortic valve replacement: first transfemoral implant in Asia. Singapore Medical Journal. 2009;50(5):534-537. [pmid: 19495528].
73 Dumonteil N, Marcheix B, Berthoumieu P, et al. Transfemoral aortic valve implantation with pre-existent mechanical mitral prosthesis. Evidence of feasibility. JACC: Cardiovascular Interventions. 2009;2(9):897-898. [pmid: 19778782].
74 Bleiziffer S, Ruge H, Mazzitelli D, et al. Valve implantation on the beating heart: catheter-assisted surgery for aortic stenosis. Dtsch Arztebl Int. 2009;106(14):235-241. [pmid: 19547639].
75 Kolettis TN, Spargias K, Stavridis GT. Combined transapical aortic valve implantation with coronary artery bypass grafting in a young patient with porcelain aorta. Hellenic J Cardiol. 2009;50(1):79-82. [pmid: 19196626].
76 Cheung A, Webb JG, Wong DR, et al. Transapical transcatheter mitral valve-in-valve implantation in a human. Annals of Thoracic Surgery. 2009;87(3):e18-e20. [pmid: 19231366].
77 Grube E, Laborde JC, Zickmann B, et al. First report on a human percutaneous transluminal implantation of a self-expanding valve prosthesis for interventional treatment of aortic valve stenosis. Catheterization & Cardiovascular Interventions. 2005;66(4):465-469. [pmid: 16208696].
78 Grube E, Laborde JC, Gerckens U, et al. Percutaneous implantation of the CoreValve self-expanding valve prosthesis in high-risk patients with aortic valve disease: the Siegburg first-in-man study. Circulation. 2006;114(15):1616-1624. [pmid: 17015786].
79 Grube E, Schuler G, Buellesfeld L, et al. Percutaneous aortic valve replacement for severe aortic stenosis in high-risk patients using the second- and current third-generation self-expanding CoreValve prosthesis: device success and 30-day clinical outcome. Journal of the American College of Cardiology. 2007;50(1):69-76. [pmid: 17601548].
80 Grube E, Buellesfeld L, Mueller R, et al. Progress and current status of percutaneous aortic valve replacement: results of three device generations of the CoreValve Revalving system. Circulation: Cardiovascular Interventions. 2008;1:167-175. [pmid: 20031675].
81 Marcheix B, Lamarche Y, Berry C, et al. Surgical aspects of endovascular retrograde implantation of the aortic CoreValve bioprosthesis in high-risk older patients with severe symptomatic aortic stenosis. Journal of Thoracic & Cardiovascular Surgery. 2007;134(5):1150-1156. [pmid: 17976442].
82 Berry C, Asgar A, Lamarche Y, et al. Novel therapeutic aspects of percutaneous aortic valve replacement with the 21F CoreValve Revalving System. Catheterization & Cardiovascular Interventions. 2007;70(4):610-616. [pmid: 17894307].
83 Berry C, Cartier R, Bonan R. Fatal ischemic stroke related to nonpermissive peripheral artery access for percutaneous aortic valve replacement. Catheterization & Cardiovascular Interventions. 2007;69(1):56-63. [pmid: 17154428].
84 Lamarche Y, Cartier R, Denault AY, et al. Implantation of the CoreValve percutaneous aortic valve. Annals of Thoracic Surgery. 2007;83(1):284-287. [pmid: 17184681].
85 Lange R, Schreiber C, Gotz W, et al. First successful transapical aortic valve implantation with the Corevalve Revalving system: a case report. Heart Surgery Forum. 2007;10(6):E478-E479. [pmid: 18187382].
86 Wenaweser P, Buellesfeld L, Gerckens U, et al. Percutaneous aortic valve replacement for severe aortic regurgitation in degenerated bioprosthesis: the first valve in valve procedure using the Corevalve Revalving system. Catheterization & Cardiovascular Interventions. 2007;70(5):760-764. [pmid: 17932876].
87 Ruiz CE, Laborde JC, Condado JF, et al. First percutaneous transcatheter aortic valve-in-valve implant with three year follow-up. Catheterization & Cardiovascular Interventions. 2008;72(2):143-148. [pmid: 18655115].
88 Bojara W, Mumme A, Gerckens U, et al. Implantation of the CoreValve self-expanding valve prosthesis via a subclavian artery approach: a case report. Clin Res Cardiol. 2009;98(3):201-204. [pmid: 19219393].
89 Geist V, Sherif MA, Khattab AA. Successful percutaneous coronary intervention after implantation of a CoreValve percutaneous aortic valve. Catheterization & Cardiovascular Interventions. 2009;73(1):61-67. [pmid: 19089940].
90 Piazza N, Schultz C, de Jaegere PP, et al. Implantation of two self-expanding aortic bioprosthetic valves during the same procedure-Insights into valve-in-valve implantation ("Russian doll concept"). Catheterization & Cardiovascular Interventions. 2009;73(4):530-539. [pmid: 19133687].
91 Piazza N, Serruys PW, de Jaegere P. Feasibility of complex coronary intervention in combination with percutaneous aortic valve implantation in patients with aortic stenosis using percutaneous left ventricular assist device (TandemHeart). Catheterization & Cardiovascular Interventions. 2009;73(2):161-166. [pmid: 19160444].
92 Tamburino C, Capodanno D, Mule M, et al. Procedural success and 30-day clinical outcomes after percutaneous aortic valve replacement using current third-generation self-expanding CoreValve prosthesis. Journal of Invasive Cardiology. 2009;21(3):93-98. [pmid: 19258637].
93 Ussia GP, Barbanti M, Tamburino C. Treatment of severe regurgitation of stentless aortic valve prosthesis with a self-expandable biological valve. Journal of Invasive Cardiology. 2009;21(3):E51-E54. [pmid: 19258652].
94 Ussia GP, Mule M, Tamburino C. The valve-in-valve technique: transcatheter treatment of aortic bioprothesis malposition. Catheterization & Cardiovascular Interventions. 2009;73(5):713-716. [pmid: 19180656].
95 Bauernschmitt R, Schreiber C, Bleiziffer S, et al. Transcatheter aortic valve implantation through the ascending aorta: an alternative option for no-access patients. Heart Surgery Forum. 2009;12(1):E63-E64. [pmid: 19233771].
96 Bollati M, Moretti C, Omede P, et al. Percutaneous aortic valve replacement in two cases at high surgical risk: procedural details and implications for patient selection. Minerva Cardioangiologica. 2009;57(1):131-136. [pmid: 19202524].
97 Asgar AW, Mullen MJ, Delahunty N, et al. Transcatheter aortic valve intervention through the axillary artery for the treatment of severe aortic stenosis. Journal of Thoracic and Cardiovascular Surgery. 2009;137(3):773-775. [pmid: 19258115].
98 Paniagua D, Condado JA, Besso J, et al. First human case of retrograde transcatheter implantation of an aortic valve prosthesis. Texas Heart Institute Journal. 2005;32(3):393-398. [pmid: 16392228].
99 Buellesfeld L, Gerckens U, Grube E. Percutaneous implantation of the first repositionable aortic valve prosthesis in a patient with severe aortic stenosis. Catheterization & Cardiovascular Interventions. 2008;71(5):579-584. [pmid: 18360844].
100 Rodés-Cabau J, Houde C, Perron J, et al. Delayed improvement in valve hemodynamic performance after percutaneous pulmonary valve implantation. Annals of Thoracic Surgery. 2008;85(5):1787-1788. [pmid: 18442588].
101 Schofer J, Schluter M, Treede H, et al. Retrograde transarterial implantation of a nonmetallic aortic valve prosthesis in high-surgical-risk patients with severe aortic stenosis: a first-in-man feasibility and safety study. Circulation: Cardiovascular Interventions. 2008;1:126-133. [pmid: 20031667].
102 Falk V, Schwammenthal EE, Kempfert J, et al. New anatomically oriented transapical aortic valve implantation. Annals of Thoracic Surgery. 2009;87(3):925-926. [pmid: 19231421].
103 Kapadia SR, Svensson L, Tuzcu EM. Successful percutaneous management of left main trunk occlusion during percutaneous aortic valve replacement. Catheterization & Cardiovascular Interventions. 2009;73(7):966-972. [pmid: 19455695].
104 Sack S, Kahlert P, Eggebrecht H, et al. Procedural developments and evolutions in percutaneous aortic valve replacement: a single-center experience. Abstract No. 629. Transcatheter Cardiovascular Therapeutics Conference. 2008. Available by searching at: www.aievolution.com/tct0801.
105 Colombo A, Chieffo A, Bande M, et al. Preliminary real world Milan and Massy experience with Edwards Sapein transcatheter heart valve implantation for patients with aortic stenosis: procedural and thiry-days outcome. Abstract No. 631. Transcatheter Cardiovascular Therapeutics Conference. 2008. Available by searching at: www.aievolution.com/tct0801.
106 Clavel M-A, Webb J, Pibarot P, et al. Comparison of the hemodynamic performance of percutaneous and surgical (stented and stentless) bioprostheses for the treatment of severe aortic stenosis Abstract No. 4783. American Heart Association Scientific Sessions. 2008. Available by searching at: http://circ.ahajournals.org/search.dtl.
107 Ye J, Cheung A, Webb J, et al. Transapical transcatheter aortic valve implantation one year collow-up in 19 patients. Abstract No. T6. American Association of Thoracis Surgery Annual Meeting. 2008. Available by searching at: http://www.aats.org/multimedia/files/AnnualMeeting/2008/AATS08-Final-Program.pdf.
108 Behan M, Hutchinson N, Trivedi U, et al. Percutaneous aortic valve implantation under sedation with 'standby' general anaesthetic. Abstract No. 620. Transcatheter Cardiovascular Therapeutics Conference. 2008. Available by searching at www.aievolution.com/tct0801.
109 Maier R, Hoedl R, Stoschitzky G, et al. Percutaneous aortic valve replacement for severe symptomatic aortic stenosis in high-risk patients: One-year experience with the CoreValve RevalvingTM System. Abstract No. 623. Transcatheter Cardiovascular Therapeutics Conference. 2008. Available by searching at: www.aievolution.com/tct0801.
110 Piazza N, Grube E, Gerckens U, et al. Procedural and 30-day outcomes following transcatheter aortic valve implantation using the Third Generation (18F) CoreValve Revalving System: Results from the multicenter, expanded evaluation registry 1 year after being CE Mark approval. Abstract No. 14. Transcatheter Cardiovascular Therapeutics Conference. 2008. Available by searching at www.aievolution.com/tct0801.
111 De Jaegere P, Piazza N, Otten A, et al. One-year clinical outcome after percutaneous aortic valve implantation. Abstract No. 92. Transcatheter Cardiovascular Therapeutics Conference. 2008. Available by searching at www.aievolution.com/tct0801.
112 Jilaihawi, Spyt, Chin, et al. Transcatheter aortic valve implantation (TAVI) with the corevalve bioprosthesis in severe aortic stenosis (AS): a comparison of survival to an untreated and an age matched open surgical population. Abstract No. P564. European Society of Cardiology Congress. 2008. Available by searching at: http://spo.escardio.org/abstract%2Dbook.
113 Jilaihawi, Chin, Logtens, et al. Importance of depth of delivery of the corevalve transcatheter aortic valve implant (TAVI): how low can you go? Abstract No. P565. European Society of Cardiology Congress. 2008. Available by searching at: http://spo.escardio.org/abstract%2Dbook.
114 Masson J-B, Ye J, Cheung A, et al. Transcatheter valve-in-valve therapy for failed aortic and mitral bioprostheses. Abstract No. 625. Transcatheter Cardiovascular Therapeutics Conference. 2008. Available by searching at: www.aievolution.com/tct0801.
115 Doss M, Martens S, Fichtelscherer S, et al. Is transcatheter based aortic valve implantation really less invasive than minimal invasive aortic valve replacement? Abstract No. T2. American Association of Thoracis Surgery Annual Meeting. 2008. Available by searching at: http://www.aats.org/multimedia/files/AnnualMeeting/2008/AATS08-Final-Program.pdf.
116 Hammermeister K, Sethi GK, Henderson WG, et al. Outcomes 15 years after valve replacement with a mechanical versus a bioprosthetic valve: final report of the Veterans Affairs randomized trial. Journal of the American College of Cardiology. 2000;36(4):1152-1158. [pmid: 11028464].
117 Prasongsukarn K, Jamieson WRE, Lichtenstein SV. Performance of bioprostheses and mechanical prostheses in age group 61–70 years. Journal of Heart Valve Disease. 2005;14(4):501-508. [pmid: 16116877].
118 Bernet FH, Baykut D, Grize L, et al. Single-center outcome analysis of 1,161 patients with St. Jude medical and ATS open pivot mechanical heart valves. Journal of Heart Valve Disease. 2007;16(2):151-158. [pmid: 17484464].