# Methods

## Key Questions

AHRQ, the sponsor of this report, originally identified four key questions to be addressed in this Technical Brief. The research team at the Duke Evidence-based Practice Center (EPC) further clarified and refined the overall research objectives and the key questions in consultation with the AHRQ Task Order Officer assigned to the project.

The key questions addressed are as follows:

Question 1. What are the different types of heart valves in use and in development (including tissue, mechanical, and percutaneous valves)?

a. What are the existing or potential U.S. Food and Drug Administration (FDA) indications for each valve (patient characteristics, etc.)?
b. What are the theoretical advantages and disadvantages of different valves for different patient populations?

Question 2. From a systematic literature scan of studies on different types of tissue and mechanical valves, describe the types of comparative studies, including basic study design, size of study, length of followup, and outcomes assessed. This literature scan will provide data to determine if a systematic review of this literature is possible and needed, and to provide needed context for understanding the evaluation and development of percutaneous heart valves.

Question 3. From a systematic literature scan of studies on different types of percutaneous heart valves, provide a synthesis of the following variables:

a. Number for each type of valve.
b. Type of studies—comparative and non-comparative randomized controlled trials (RCTs), non-randomized controlled clinical trials, case series, etc.
c. Variables associated with surgery (implantation technique), setting, etc.
d. Size of studies/length of followup.
e. Patient population/concurrent and prior treatments.
f. Hemodynamic success rates reported.
g. Harms reported.

Question 4. What are the variables associated with surgery or setting that may impact outcomes for percutaneous heart valves?

a. What are the different implantation techniques (i.e., position of implantation, delivery, and axis techniques)? What is the evidence of success (i.e., absence of narrowing and regurgitation) and harms?
  i. For percutaneous aortic valves.
  ii. For percutaneous mitral valves.

## Sources of Information and Review Methods

The sources of information consulted and review methods used by the Duke team varied considerably by key question. Question 1 involved gathering and collating information from the FDA, device manufacturers, and other sources. Question 2 and Questions 3–4 required separate literature reviews using distinct sources, search strategies, and review methods. Because of this variability, we describe the methods used for each key question separately.

### Question 1. Heart Valves in Use and Development

We used four approaches to identify heart valves now in use or in development. First, we identified valves described in the published literature abstracted in answer to Question 2 (conventional valves) and Questions 3 and 4 (percutaneous valves). Next, we generated a list of valve manufacturers based on the published literature and expert knowledge. On our behalf, the Scientific Resource Center (SRC) at the Oregon EPC then contacted 14 companies believed to manufacture percutaneous heart valves and requested information on percutaneous valves in use or in development. (They attempted to contact a 15th manufacturer, but were unable to identify any current contact information for the company.) Of the 14 manufacturers contacted, 7 did not respond, 6 responded that they had nothing to submit, and 1—Edwards Lifesciences, LLC—responded with the requested information. Finally, we supplemented these approaches by searching the Web sites of valve manufacturers.

To identify valves with FDA approval, we first contacted the FDA, who provided a list of approved valves. For valves known to us but not included in the list provided by the FDA, we searched the Internet (via Google) using terms for the manufacturer, the specific valve, and “FDA.” Using this strategy, we discovered and accepted manufacturer press releases claiming FDA approval.

Percutaneous heart valves are an emerging technology, and none are FDA approved. For this valve class, we relied on the published literature and experts to describe potential FDA indications.

To determine the theoretical advantages and disadvantages of different valves for different populations, we relied on discussions and recommendations in clinical guidelines, review articles, and consultations with experts. Using these sources, we developed a narrative description of the valve classes, goals in valve design, and the theoretical advantages and disadvantages of different types of valves.

### Question 2. Studies Comparing Various Types of Conventional Heart Valves

Approach. For Question 2, we scanned the existing literature comparing different types of conventional (i.e., tissue and mechanical) heart valves in order to determine whether a systematic review of this literature is possible and needed, and to provide a context for understanding the development and evaluation of percutaneous heart valves. We sought to describe the available comparative studies in terms of the number of available studies, interventions compared, basic study design, size of study, length of followup, and outcomes assessed.

We began by searching for relevant, high-quality systematic reviews. We then expanded beyond these to a scan of available RCTs and select observational studies.

Literature sources and search strategies. We used separate strategies to identify systematic reviews, RCTs, and observational studies:

- For potentially relevant systematic reviews, we searched PubMed^®^ (1949 to October 17, 2008) using the detailed search strategy given in Appendix A. We also searched the Cochrane Database of Systematic Reviews, the Database of Abstracts of Reviews of Effects, and the Health Technology Assessment Database using the terms “heart valve” OR “heart valve prosthesis.”
- We identified potentially relevant RCTs in two ways: (1) By reviewing the individual studies included in the systematic reviews that met our full-text inclusion criteria; and (2) by searching PubMed^®^ (1949 to October 17, 2008) using the detailed search strategy given in Appendix A.
- We identified potentially important observational studies primarily by reviewing the individual studies included in the systematic reviews that met our full-text inclusion criteria. A few additional observational studies were picked up by the RCT search described in Appendix A. We also searched PubMed^®^ (search date December 13, 2008) for recent (published during the past 5 years) observational studies that were large (n ≥ 1000), or that had followup of 10 years or longer, or that evaluated valves not studied in RCTs using the detailed search strategy described in Appendix A.

Screening for inclusion/exclusion—systematic reviews. A single reviewer screened the titles and abstracts of all citations for potential inclusion. Articles were included if they concerned conventional heart valves and appeared to be a review article.

Citations included at the title-and-abstract stage were reviewed in full-text form independently by two researchers. Articles meeting the following criteria were included for data abstraction:

- The article was a systematic review, defined as a review including both a Methods section describing a search strategy and analytic approach, and abstractions of primary literature; and
- The review directly compared two or more different types of conventional heart valves; and
- The review concerned valve replacement (rather than repair); and
- The review focused on adults (all patients ≥ 18 years of age or, if mixed population, then either 80 percent adults or results reported separately for adults); and
- The review was published in English in the year 2000 or later.

When the two reviewers arrived at different conclusions about whether to include or exclude an article, they were asked to reconcile the difference.

Screening for inclusion/exclusion—RCTs. A single investigator screened titles and abstracts and then full texts of potentially relevant RCTs. The inclusion criteria applied at both screening stages were:

- Comparison of two or more heart valves for valve replacement (rather than repair); and
- Randomized allocation to treatment; and
- Study conducted in adults (all patients ≥ 18 years of age or, if mixed population, then either 80 percent adults or results reported separately for adults); and
- Study published in English.

If there was any uncertainty about whether an article should be included, a second investigator was consulted.

Screening for inclusion/exclusion—observational studies. A single investigator screened titles and abstracts and then full texts using the following inclusion criteria:

- Observational study design; and
- Comparison of two or more heart valves for valve replacement (rather than repair); and
- Large study population (n ≥ 1000) or followup ≥ 10 years or study evaluated a valve not evaluated in RCTs; and
- Study conducted in adults (all patients ≥ 18 years of age or, if mixed population, then either 80 percent adults or results reported separately for adults); and
- Study published in English.

A second investigator was consulted in cases where there was uncertainty about whether an article should be included.

Data abstraction. For Question 2, we completed detailed evidence tables only for the included systematic reviews (Appendix B, Evidence Table 1). Data abstracted included the number and designs of included studies, patient descriptors, heart valves compared, and outcomes reported.

For RCTs and observational studies that met our inclusion criteria, we abstracted basic information on the interventions compared, study design, size of study, length of followup, and outcomes assessed into summary tables (Appendix C, Tables C1 and C2).

Quality assessment. The methodological quality of the included systematic reviews was evaluated independently by two investigators using a quality assessment tool developed specifically for this project. This tool was adapted from a similar instrument used in a previous evidence report prepared for AHRQ,22 which in turn was based on the Quality Of Reporting Of Meta-analyses (QUOROM) statement.23

The 10 quality criteria assessed were stated in question form; possible responses were “Yes,” “Partially,” “No,” or “Can’t tell.” The criteria used are presented in detail in Appendix D. When the two investigators disagreed in their assessments, they met to reconcile the difference. The results of quality assessments for individual systematic reviews are reported in Evidence Table 1 (Appendix B).

The RCTs and observational studies reviewed for this question were not assessed for methodological quality.

### Question 3. Studies of Percutaneous Heart Valves

Approach. We scanned the existing published and gray literature on different types of percutaneous heart valves to synthesize information on the variables specified in Question 3. We limited our search to human studies of percutaneous heart valves in adults.

Literature sources and search strategies. We searched PubMed^®^ and EMBASE^®^ through October 15, 2009, for relevant published studies using the detailed search strategies given in Appendix A.

We also conducted an extensive search of the gray literature for this question (last search date December 31, 2008). We were assisted in this effort by a librarian with expertise in gray literature searching, who suggested sources and search terms. The gray literature sources consulted, search terms used, and results are described in Table 1.

Table 1 Percutaneous heart valves gray literature sources, search terms, and results (last search date December 31, 2008)

Source | Search Term(s) | Restrictions | Number of Citations Identified | Number of Eligible Studies
General gray literature sources
Google Scholar (http://scholar.google.com) Advanced Scholar Search: http://scholar.google.com/advanced_scholar_search?hl=en&lr= | All of the words: “percutaneous,” “heart,” and “valve” | - In the title of the article; - In the “Medicine, Pharmacology, and Veterinary Science” subject area; - Published 2003–2008 | 56 | 0
CRISP (Computer Retrieval of Information on Scientific Projects; http://crisp.cit.nih.gov/) Query Form: http://crisp.cit.nih.gov/crisp/crisp_query.generate_screen | “percutaneous” AND “valve” | - All award types; - All IRGs; - All institutes and centers; - Fiscal years 2003–2008 | 12 | 0
The New York Academy of Medicine Grey Literature Report (http://www.nyam.org/library/pages/grey_literature_report) Search under “Search the Grey Literature Collection” | Subject Keyword “heart valve” anywhere in text or title | None | 37 | 0
OAlster (University of Michigan collection of free, otherwise difficult- to-access resources from 327 institutions; http://www.oaister.org) Search page (http://quod.lib.umich.edu/cgi/b/bib/bib-idx?c=oaister;page=simple) | “percutaneous” AND “heart” AND “valve” | None | 58 | 0
NICHSR (National Library of Medicine, National Information Center of Health Services Research and Health Care Technology (http://wwwcf.nlm.nih.gov/hsr_project/home_proj.cfm) | “percutaneous” | None | 15 | 0
WHO Publications (http://www.who.int/publications/en) | “percutaneous heart valve” | None | 69 | 0
Abstracts from scientific meetings
American Heart Association (AHA; http://scientificsessions.americanheart.org/portal/scientificsessions/ss/); Advanced Search: http://circ.ahajournals.org/search.dtl | All of the words: “percutaneous,” “heart,” and “valve” | - In title or abstract; - Include AHA Scientific Sessions Abstracts; - 2003–2008 | 30 | 1
American Cardiology Association (ACC; http://www.acc.org/) Search page: http://content.onlinejacc.org/search.dtl | All of the words: “percutaneous,” “heart,” and “valve” | - In title or abstract; - All JACC journals 2003–2008 | 10 | 0
Transcatheter Cardiovascular Therapeutics (TCT) Abstracts 2008 meeting Search page: http://www.aievolution.com/tct0801 | “percutaneous heart valve” | All abstract categories | 0 | 0
Transcatheter Cardiovascular Therapeutics (TCT) Abstracts 2008 meeting Search page: http://www.aievolution.com/tct0801 | “percutaneous” “transapical” “transcatheter” | All abstract categories | 211 (percutaneous) 3 (transapical) 15 (transcatheter) | 7
European Society of Cardiology (ESC) http://www.escardio.org/Pages/index.aspx) Search page: http://spo.escardio.org/abstract-book/topic.aspx | Browsed “surgery and intervention in valve disease” topic | ESC Congress 2007 or ESC Congress 2008 | 13 (2007) 16 (2008) | 1 (2 abstracts)
American Association of Thoracic Surgery (AATS) http://www.aats.org/multimedia/files/AnnualMeeting/2008/AATS08-Final-Program.pdf | Browsed (not possible to search using keywords/subject terms) | AATS Annual Meetings 2007 and 2008 | NA | 2
Society of Thoracic Surgeons (STS) http://www.sts.org | “transcatheter” “percutaneous” “transapical” | STS Annual Meeting 2008 | NA | 0
Ongoing trials
ClinicalTrials.gov (http://www.clinicaltrials.gov) Basic Search: http://www.clinicaltrials.gov/ct2/search | (percutaneous OR transapical) AND (heart OR valve) | None | 17 | 4

Abbreviations: IRGs = institutional research grants; JACC = Journal of the American College of Cardiology.

Finally, colleagues working in AHRQ’s Effective Health Care Program at Oregon Health & Science University contacted companies known or believed to manufacture percutaneous heart valves on our behalf to request any additional information they wished to submit in the form of “Scientific Information Packets.” Requests to companies were sent out on August 5, 2008; the deadline for responding was September 16, 2008. Table 2 provides a list of the companies contacted and their responses.

Table 2 Requests for Scientific Information Packets and responses from companies

Company | Response
Cardiac Dimensions | Telephone response on 5 August 2008 nothing to submit
CoreValve, Inc. | No response
Direct Flow Medical, Inc. | No response
Edwards Lifesciences, LLC | Hardcopy Scientific Information Packet received16 September 2008
Endoluminal | Unable to contact; no contact information available from any source, may no longer be a company
Endovalve | No response
Evalve, Inc. | E-mail dated 7 August 2008 nothing to submit
Hansen Medical | E-mail dated 6 August 2008 nothing to submit
JenaValve Technology, Inc. | No response
Medtronic, Inc. | E-mail dated 29 August 2008 nothing to submit
MiCardia | E-mail dated 5 August 2008 nothing to submit
Mitralign, Inc. | No response
Myocor, Inc. | No response
Sadra Medical | No response
Viacor, Inc. | E-mail dated 5 August 2008 nothing to submit

Screening for inclusion/exclusion—published studies. Citations to published studies retrieved through searches of PubMed^®^ and EMBASE^®^ were supplemented by information provided in the Scientific Information Packet submitted by Edwards Lifesciences, LLC. A single reviewer screened the titles and abstracts of all citations for potential inclusion. All citations that appeared to report primary data on studies of percutaneous heart valves in humans were included at this stage, with no limit by language or heart valve position (e.g., aortic vs. mitral).

Citations included at the title-and-abstract stage were reviewed in full-text form independently by two researchers. Articles meeting the following criteria were included for data abstraction:

- Interventions included percutaneous heart valves; and
- Study involved valve replacement (rather than repair); and
- Primary data were reported; and
- Study was conducted in humans; and
- Study was conducted in adults (all patients ≥ 18 years of age or, if mixed population, then either 80 percent adults or results reported separately for adults); and
- At least 1 clinical outcome was reported (e.g., mortality, hemodynamic parameters of success, successful implantation rates); and
- Study was published in English.

Note that no restrictions were imposed regarding:

- Study design (all designs acceptable); or
- Sample size (n ≥ 1 acceptable).

When the two reviewers arrived at different conclusions about whether to include or exclude an article, they were asked to reconcile the difference.

Screening for inclusion/exclusion—gray literature. A single investigator searched the general gray literature sources listed in Table 1 and screened the material identified for potential relevance using the inclusion/exclusion criteria described above for published studies.

A single investigator also searched the sources listed in Table 1 for potentially relevant abstracts from recent scientific meetings. Titles and abstracts were screened online, and potentially relevant abstracts were then reviewed in full using the inclusion/exclusion criteria described above for published studies. Abstracts meeting the inclusion criteria were further screened to eliminate those abstracts that duplicated information reported more fully in published studies.

A single investigator searched ClinicalTrials.gov for potentially relevant ongoing studies of percutaneous heart valves.

Finally, a single investigator reviewed information on four relevant registries of percutaneous heart valve implantation included in the Scientific Information Packet provided by Edwards Lifesciences, LLC.

Data abstraction. For Question 3, we created detailed evidence tables only for published studies (Appendix B, Evidence Table 2). Data abstracted included: date of publication; country; study design; study objectives; duration of followup; number, age, and sex of participants; indication for percutaneous heart valve; valve name; size of catheter; implementation approach; implantation rates; and clinical outcomes, including hemodynamic measurements and 30-day mortality rates, complications, and device dysfunction rates.

Important data from the included gray literature and Scientific Information Packets were abstracted into summary tables included in the Results section.

Purely descriptive statistics are used to summarize and analyze the data abstracted from the fully published reports, as is appropriate for a horizon scan of literature comprised solely of non-comparative studies.

Quality assessment. The studies included for this question were not formally assessed for methodological quality.

### Question 4. Variables that May Affect Outcomes for Percutaneous Heart Valves

Approach. Question 4 focused on variables associated with surgery or setting that may impact outcomes for percutaneous heart valves. In consultation with experts in cardiology and cardiac surgery, we elected to broaden our focus beyond the specific variables listed in the question to include other variables that usually impact outcomes for surgical procedures and that we expected would be reported in published reports identified by our search strategy. In the end, we considered six general categories of variables: (1) prosthesis characteristics; (2) implantation approach; (3) treatment setting; (4) operator characteristics; (5) type of anesthesia; and (6) patient characteristics. The specific variables considered under each category are listed in Table 3.

Table 3 Variables potentially associated with outcomes for percutaneous heart valves

Prosthesis Characteristics:; - - Valve design; - - Valve size; - - Catheter size; - - Deployment; - - Post-deployment adjustment; Implantation Approach:; - - Transfemoral antegrade; - - Transfemoral retrograde; - - Transapical; Treatment Setting:; - - Surgical operating room; - - Cardiac catheterization suite; - - Cardiac catheterization suite enhanced with operating room features (“hybrid” setting); Operator Characteristics:; - - Medical or surgical specialty; - - Experience; Type of Anesthesia:; - - General anesthesia; - - Conscious sedation; Patient Characteristics:; - - Medical conditions and comorbidities; - - Operative risk; - - Indication for the procedure

For the purpose of answering this question, we focused on device implantation success rates and 30-day survival rates as outcome measures. These two outcomes were consistently reported in most of the studies, and they serve as reasonable proxy measures for the feasibility of delivering prosthetic heart valves percutaneously, as well as for short-term clinical outcomes.

Sources and methods. For Question 4, we considered a subset of the literature identified for Question 3, namely, the 62 fully published reports that met the inclusion criteria for that question. The methods used to search the published literature, screen potentially relevant citations, and abstract and evaluate data are described above, under Question 3. For Question 4 we also consulted with experts in cardiology and cardiac surgery and incorporated information and perspectives from pertinent, published review articles.6,8,24–30

For the present question, we excluded data presented at scientific meetings but not yet published in peer-reviewed journals for the following reasons: (1) the data reported in meeting abstracts were insufficient to create sufficiently detailed evidence tables; (2) data presented at scientific meetings often differ from those that later appear in published reports; (3) data presented at meetings are often derived from a subset of patients whose data have undergone only preliminary analysis; and (4) insufficient data are usually presented in the abstracts to identify new patients in ongoing series for which preliminary findings were previously published.

## Peer Review Process

We employed internal and external quality-monitoring checks through every phase of the project to reduce bias, enhance consistency, and verify accuracy. Examples of internal monitoring procedures include the following: three progressively stricter screening opportunities for each article (abstract screening, full-text screening, and data abstraction); involvement of at least two individuals (an abstractor and an over-reader) in each data abstraction; and agreement of at least two investigators on all included studies.

Our principle external quality-monitoring device is the peer review process. Nominations for peer reviewers were solicited from several sources, including the clinical content experts on the Duke research team, AHRQ, and staff at the SRC at the Oregon EPC. The list of nominees was forwarded to AHRQ for vetting and approval. A list of peer reviewers who submitted comments on a draft version of this report is provided in Appendix E.