# Introduction

## Background

As the proportion of older adults increases in the U.S. population, the prevalence of degenerative heart valve disease is also increasing. Calcific aortic stenosis (narrowing) and ischemic and degenerative mitral regurgitation (leakage) are the most common valvular disorders in adults aged 70 years and older.1,2 For patients with severe valve disease, heart valve replacement involving open heart surgery can improve functional status and quality of life.3–5 A variety of conventional mechanical and bioprosthetic heart valves are readily available. However, some individuals are considered too high risk for open heart surgery. These patients may benefit from a less invasive procedure.

Percutaneous heart valve replacement is a relatively new interventional procedure involving the insertion of an artificial heart valve using a catheter, rather than through open heart surgery.6 The portal of entry is typically either via the femoral vein or artery, or directly through the myocardium via the apical region of the heart. An expandable prosthetic heart valve is delivered and deployed at the site of the diseased native valve. The percutaneous heart valve replacement procedure usually takes less time to perform and is less invasive than open heart surgery.

The Agency for Healthcare Research and Quality (AHRQ) has commissioned this Technical Brief to:

- Describe the types of conventional and percutaneous heart valves now in use or in development and their theoretical advantages and disadvantages for different patient populations.
- Describe the literature comparing various types of conventional heart valves in adults and determine whether a systematic review of this literature is feasible and needed.
- Describe the literature evaluating percutaneous heart valves in adults, including the patient populations and major outcomes studied to date.
- Describe implantation techniques for percutaneous heart valves and the factors associated with surgery or setting that may impact outcomes.

The intended audience of this Technical Brief includes policymakers, decisionmakers for third-party payers, clinicians, patients, and investigators.

## Epidemiology

Aortic stenosis and mitral regurgitation are the most common valvular disorders in older adults. The prevalence of at least moderate aortic stenosis in the general population increases from 2.5 percent at age 75 to 8.1 percent at age 85.^7^ Once moderate aortic stenosis (valve area 1.0 to 1.5 cm^2^) is present, the valve area decreases at an average rate of 0.1 cm^2^ per year. After a long latent period, patients may develop symptoms of angina, syncope, or heart failure, with moderate or, more commonly, severe stenosis. The decision to replace the aortic valve is based largely on the presence or absence of symptoms.8 After the onset of symptoms, the risk of sudden death is high, and survival averages 2 to 3 years.9–12

Aortic valve replacement (AVR) is the most common heart valve operation, accounting for 60 to 70 percent of all valve surgery performed in the elderly. In adults with severe, symptomatic, calcific aortic stenosis, AVR is the only effective treatment.8 In patients with symptomatic aortic stenosis, AVR improves symptoms, functional status, and survival. The 2006 American College of Cardiology (ACC)/American Heart Association (AHA) guidelines make a Class I recommendation for AVR in symptomatic patients with severe aortic stenosis.8 AVR is also recommended in certain circumstances for patients with severe stenosis who are asymptomatic, and for patients with mild to moderate stenosis undergoing coronary artery bypass graft (CABG) when there is evidence that progression may be rapid.8 Aortic valve repair using balloon valvuloplasty has been performed in older adults, but results in poor outcomes and is only considered for patients considered too high risk for valve replacement.

AVR carries a perioperative mortality risk of approximately 3.0 to 4.0 percent, increasing to 5.5 to 6.8 percent when combined with coronary artery bypass grafting.8 In patients over the age of 65, the average in-hospital mortality is 8.8 percent in low-volume centers.8 Operative risks can be estimated with validated online risk calculators7,13–15 that include age, sex, functional status, cardiac factors, and medical comorbidity. Although age alone is not a contraindication to surgery, a survey of Dutch cardiologists found age to be a primary determinant in the decision to recommend AVR.16 Based on high-risk features or age, a significant subset of patients with indications for valve surgery are deemed ineligible for conventional valve replacement.17 One survey of 92 European heart centers found that 31.8 percent of patients with severe, symptomatic, single valve disease did not undergo intervention, most frequently because of comorbidities.18

Mitral valve regurgitation affects approximately 2.3 percent of 60- to 69-year-olds and 5.5 percent of adults older than 70.^1^ It is the second most common reason for valve surgery in older adults. The most common causes of mitral regurgitation in older adults are myxomatous degeneration and ischemic heart disease.19–21 With mild to moderate disease, individuals may remain asymptomatic for many years. Patients with chronic severe mitral regurgitation have a high likelihood of becoming symptomatic after 6 to 10 years. The 2006 ACC/AHA guidelines recommend mitral valve surgery for patients with chronic severe mitral regurgitation who have impaired functional status or meet specific hemodynamic criteria (Level of Evidence = C, which represents consensus opinion of experts, case studies, or standard of care).8 In contrast to the recommendations for patients with aortic stenosis, valve repair—rather than replacement—is considered an option and is recommended for “the majority of patients with severe chronic mitral regurgitation who require surgery.”8

## Conventional Valve Replacement

Conventional valve replacement requires general anesthesia, a sternotomy, and heart-lung bypass. The surgeon removes the diseased valve and replaces it with a mechanical or biological valve. Surgery averages 3 to 6 hours, and most patients are discharged from the hospital after 5 to 6 days. Recovery generally takes 6 to 12 weeks. Patients who receive a mechanical valve will be placed on life-long anticoagulation that requires regular monitoring. Like mechanical valves, bioprosthetic heart valves are readily available and have a simple and standard implantation technique. Unlike mechanical valves, they do not require chronic anticoagulation. Bioprosthetic heart valves are also less durable than mechanical valves. Minimally invasive valve surgery is similar to traditional surgery but uses smaller incisions, with the potential advantages of less bleeding, less pain, and decreased recovery time. All of these procedures have associated cardiovascular risks, including stroke.

Selecting the specific heart valve involves both clinical and technical considerations. Clinical considerations include: concurrent indications for anticoagulation (e.g., chronic deep venous thrombosis) or contraindications to anticoagulation; the patient’s life expectancy; and patient preference. Technical considerations include: surgeon experience with particular valves; the technical difficulty of implanting differing valves; valve durability; and the size of the valve annulus.

## Percutaneous Valve Replacement

Percutaneous (or “catheter-based” or “transcatheter”) heart valve replacement is an experimental procedure in which a valve is crimped onto a catheter and deployed without removing the diseased native valve. The procedure does not require heart-lung bypass. Potential advantages include decreased recovery time and lower surgical risk. Potential disadvantages include a greater risk for valve migration (since the valve is not sewn into place), complications associated with catheter-based delivery, and uncertain valve durability.

Six percutaneous techniques have been described in the published literature. In the early stages of development, percutaneous valves were delivered via the femoral vein or artery. More recently, they have also been successfully implanted through the heart wall (the “transapical” approach), through the subclavian artery, through the axillary artery, and through the ascending aorta. For the purpose of this report, we consider the femoral vein, femoral artery, transapical, subclavian artery, axillary artery, and ascending aorta approaches all to fall within the scope of percutaneous heart valve replacement.

The procedure using the transapical approach is performed by cardiac surgeons, using direct left ventricular apical puncture through a small thoracotomy. The procedure does not require a sternotomy. The other five approaches all involve cannulation of an artery or vein. Of these, four approaches (femoral artery, subclavian artery, axillary artery, and ascending aorta) are considered to be retrograde approaches because the catheter is directed through a vessel against the direction of blood flow. The femoral vein approach, by contrast, is considered to be an antegrade (or anterograde) approach because the catheter is directed to the heart through the venous system, in the direction of blood flow.