# Discussion

## Summary of Findings

Conventional mechanical and bioprosthetic heart valves are readily available in the U.S. market. Tissue-engineered valves are in development, but none currently have an FDA indication. Important clinical issues in selecting a valve include the technical difficulty of valve replacement, valve durability, hemodynamic performance, complication rates, the need for anticoagulation, and effects on patient-important outcomes such as functional status and mortality. From a policy perspective, device costs, procedure costs, availability of specific valve types, and availability of experienced operators are additional considerations.

A large number of published RCTs and observational studies have evaluated the comparative effectiveness of conventional heart valves in adults. Existing systematic reviews compare mechanical with bioprosthetic valves in the aortic or mitral and tricuspid position, but all of these reviews have important methodological limitations that may bias results. A recent high-quality review compared stented with stentless bioprosthetic valves and found mixed short-term hemodynamic benefits for stentless valves, but with the tradeoff of longer cross-clamp and heart-lung bypass times.35 Only one review compared two different stented bioprosthetic valves,39 and we did not identify any systematic reviews comparing differing mechanical valves.

Systematic reviews that aim to compare valves are challenging. Surgical and anesthetic techniques have improved over time, potentially confounding comparisons across time periods. Valve designs have also changed over time, and those changes are not always reliably reflected by changes to valve names; moreover, valve names are not reported in a uniform manner, complicating accurate valve classification. Many currently marketed valves have not been evaluated in long-term RCTs, necessitating the incorporation of observational studies, which are more subject to bias.

Percutaneous heart valves have been developed and evaluated by at least seven companies. Some of these valves are approved for use in Europe, and most of the published literature originates from this region. The current literature consists of case series and case reports focusing almost exclusively on the Edwards SAPEIN THV valve and CoreValve ReValving Systems. The peer-reviewed literature describes just over 900 patients, assessed as being at high risk for conventional valve replacement, who have received these valves. This initial experience is promising. Rates of successful implantation are high, and 30-day survival is 86 percent and is lower than mortality predicted by the EuroSCORE. In lower risk patients, the perioperative mortality rate for surgical AVR is approximately 3 to 4 percent, increasing to 5.5 to 6.8 percent when combined with coronary artery bypass grafting.8

The first percutaneous heart valve replacement procedures were conducted by accessing the venous system via the femoral vein and passing a catheter through the septum of the heart to reach (and traverse) that aortic valve. This antegrade approach via the femoral vein now appears to have been replaced by one of two emerging approaches: (1) a retrograde approach via the femoral artery; or (2) a transapical approach via the apex of the heart. Three other retrograde approaches via the subclavian or axillary artery or the ascending aorta have also been reported. Unlike the antegrade approach via the femoral vein, retrograde approaches do not require perforating and traversing the cardiac septum but present important technical challenges, in large part because of the calcified and tortuous arteries that must be navigated with a relatively large catheter. In contrast, the more recently developed transapical approach obviates the need for maneuvering a catheter through either arteries or veins, but it requires making an incision in the chest wall and traversing the myocardium.

All six percutaneous approaches reported in the published literature may require some additional training of cardiac surgeons or interventional cardiologists, as well as some modifications to existing catheter labs or operating suites. To date, few groups in the United States have significant experience with percutaneous heart valve replacement. Although the initial experience demonstrates that percutaneous heart valves can be implanted with good short-term success, longer term survival, valve durability, and complication rates are unknown. Even comparison of short-term success to historical controls is problematic because predicted mortality is based on imperfect risk prediction models that were developed for other cardiac surgeries. A further limitation of the extant literature is the subjective nature of patient selection as “too high risk for surgery,” making appropriate patient selection less certain. The ongoing PARTNER clinical trial that compares percutaneous heart valves with conventional valves will be critical in comparing the relative safety and efficacy of these technologies.33

## Future Research

The long-term durability of mechanical heart valves is well established and has been shown to be superior to that of early generation bioprosthetic valves. Newer generation bioprosthetic valves are purported to have improved durability. Since bioprosthetic valves do not require chronic anticoagulation, durability is a critical issue in determining at what age to recommend them instead of mechanical valves. An updated, high-quality systematic review could address this issue. An updated review may also be able to evaluate specific valves within each class, including currently marketed newer vs. older valves, and valves with different design features (e.g., mechanical bileaflet vs. tilting disc). Because the number of direct comparisons is limited for many valves and some valve classes, indirect comparisons using network meta-analysis may be useful. A recent observational study using Medicare Claims data found that bioprosthetic valves were associated with a slightly lower risk of death and complications, but a higher risk of reoperation in older adults undergoing isolated AVR.41 Claims data provide limited information for case-mix adjustment. Recognizing that RCTs are not practical for all comparisons, an observational study utilizing claims data coupled with clinical databases could improve case-mix adjustment and estimates of comparative effectiveness.

For percutaneous heart valves, the potential research agenda is broad. What are the complication rates, durability, and effects on mortality and health-related quality of life? How do these valves compare with conventional valve replacement in lower risk patients? Which procedural and setting factors, including procedural volume, are related to clinical outcomes? How does PHV replacement impact quality of life? How do discharge rates to extended care facilities, rates of rehospitalization after valve placement, and changes in functional status compare to other treatment options? In which patient populations are percutaneous heart valves indicated? The ongoing PARTNER trial will address the efficacy of percutaneous heart valves compared with medical treatment in high-risk patients, and their efficacy compared with conventional valves in patients at the higher range of acceptable risk for surgical replacement.33

If percutaneous heart valves become FDA approved, a prospective registry to track the specific devices implanted and the clinical characteristics of recipients could be linked to Medicare claims data for subsequent analysis.

We identified specific opportunities for improved reporting that would facilitate comparative effectiveness studies. Standardized reporting of methods and outcomes of percutaneous heart valve replacement is especially important in light of the evolution of this technology. At least six different approaches have been reported to date. Detailed reporting of technical factors that may be associated with outcomes—such as details of the implantation approach and characteristics of the operators—would allow for retrospective analysis. Future research could also provide data on the relative costs associated with PHV procedures.

Selection of heart valves involves a number of trade-offs. From the surgeon’s perspective, some valves require greater technical expertise and operating times. From the patient’s perspective, valve durability and the related risk for reoperation, complication rates, and the need for chronic anticoagulation are all pertinent considerations. From the policymaker’s perspective, valve prosthesis costs, costs over the life of the valve (including anticoagulation monitoring for mechanical valves), and access to competing valve replacement options may be relevant considerations. Percutaneous heart valves, if FDA approved, will introduce a new option for patients who are currently deemed too high risk for conventional valve replacement. Because these patients have multiple competing risks for mortality, the effects on all-cause mortality and health-related quality of life are uncertain. From a societal perspective, the introduction of percutaneous valves may require investment in clinician training, redesign of procedural suites, and direct costs for heart valve replacement in a population previously not eligible. If percutaneous valves are proved effective in high-risk patients, a further consideration is whether to extend this procedure to lower risk patients because of its potential for lower morbidity and lower costs. Complex clinical, reimbursement policy, and regulatory questions such as these could be addressed in part by decision modeling. For example, decision modeling could simultaneously consider the effects of patient populations (e.g., age, comorbid conditions), valve characteristics (e.g., durability), clinical issues (e.g., other indications for anticoagulation), valve-specific complication rates (e.g., major bleeding), costs, and patient preferences on survival and health-related quality of life.

## Conclusions

Because the U.S. population is aging and aortic and mitral valve disease is age-related, heart valve replacement is an important issue both clinically and from the perspective of healthcare policy. Conventional heart valve replacement is a well-established intervention with many available device options, and current evidence suggests similar outcomes with mechanical and bioprosthetic valves. However, current evidence syntheses do not provide sufficient evidence to select specific valves within each of these categories.

Many older adults are not currently candidates for conventional heart valve replacement, or may be candidates for heart valve replacement, but are at especially high risk for complications associated with open-heart surgery. Percutaneous valve replacement has been demonstrated to be feasible for aortic stenosis, and short-term outcomes are promising. Several companies are developing these valves, and the reported clinical experience is increasing rapidly. Percutaneous valves have the potential to expand access to valve replacement for a large group of older adults with severe valve disease and concurrent medical conditions that currently preclude surgery. Percutaneous valves also have the potential to substitute for some conventional valve replacements and expand the indications for valve replacements. However, existing data are inadequate to determine the most appropriate clinical role for these valves or the specific patient populations for whom these valves might eventually be indicated. Many unanswered questions remain pertaining to the effects—intended or unintended—of expanding the clinical indication for percutaneous heart valve replacement to groups of patients in whom this treatment modality has not yet been evaluated.

Decision modeling, coupled with high-quality systematic reviews, could inform clinical and policy decisions in the near future. Findings from the ongoing PARTNER clinical trial33 should yield important efficacy data when they become available. Over the longer term, device registries could be established for the purpose of evaluating comparative effectiveness since randomized trials may not be feasible for some clinically important questions.