# Appendixes

Appendix A Exact Search Strategies

Appendix B Evidence Tables

Appendix C Additional Tables Relevant to Question 2

Appendix D Criteria Used To Assess the Quality of Systematic Reviews Included for Question 2

Appendix E Peer Reviewers