# Peer Reviewers

The Duke Evidence-based Practice Center is grateful to the following peer reviewers who read and commented on a draft version of this report:

- Thanos Athanasiou, M.D., Ph.D.; St Mary’s Hospital; London, UK
- Ted Feldman, M.D.; Evanston Hospital; Evanston, IL
- David Holmes, M.D.; Mayo Clinic; Rochester, MN
- Shahbudin Rahimtoola, M.D.; Los Angeles County and University of Southern California Medical Center; Los Angeles, CA
- Jeffrey Shuhaiber, M.D.; Cincinnati Children’s Hospital Medical Center; Cincinnati, OH
- John Webb, M.D.; St. Paul’s Hospital; Vancouver, BC, Canada
- T. Bruce Ferguson, Jr., M.D.; East Carolina Heart Institute; Greenville, NC