# Criteria Used To Assess the Quality of Systematic Reviews Included for Question 2

The following 10 criteria were used to assess the quality of systematic reviews included for Question 2 (evaluating comparisons of various types of conventional heart valves). Possible responses were “Yes,” “Partially,” “No,” or “Can’t tell.” Text in italics provides notes on how to interpret and operationalize the various criteria.

The quality assessment tool described here was adapted from a similar instrument used in a previous evidence report prepared for the Agency for Healthcare Research and Quality (AHRQ),1 which in turn was based on the Quality Of Reporting Of Meta-analyses (QUOROM) statement.2

1. Was a focused clinical question clearly stated?
  For “yes,” should at least identify population and interventions; does not have to be in PICO format ([underlined: P]atient population, [underlined: I]ntervention, [underlined: C]omparison, [underlined: O]utcomes).
2. Was the search for relevant studies detailed and exhaustive?
  Consider and rate 2 components: (a) Search methods described in enough detail to permit replication? (b) Databases and search terms appropriate? Consider any restrictions imposed (e.g., years, age groups, language).
3. Were inclusion/exclusion criteria clearly defined and appropriate?
  Consider and rate 2 components: (a) Were the criteria specified clearly enough to permit replication? (b) Were these criteria likely to capture all relevant studies? Consider criteria related to study population, intervention, outcomes, and study design.
4. Were the primary studies evaluated for quality, and were quality assessments done appropriately?
  Consider and rate 2 components: (a) Was study quality assessed? (b) Was quality assessment performed using a validated instrument?
5. Were assessments of studies reproducible?
  Consider and rate 2 components: (a) Did 2 or more independent raters abstract data? (b) Was an appropriate method used for resolving disagreements?
6. Were analyses conducted to measure variability in effect?
  Consider and rate 2 components: (a) Was there a check for heterogeneity statistically or graphically? (b) Were possible sources of any observed heterogeneity explored (e.g., differences in study design or population)?
7. Were results combined appropriately?
  Was an accepted quantitative or qualitative method of pooling used?
8. Was publication bias assessed?
  Consider whether any of the following methods were employed: Funnel plots, test statistics, or search of trials registry for unpublished studies.
9. Were both benefits and harms assessed?
10. Were the author’s conclusions supported by the data presented?

## References to Appendix D

1 Marinopoulos S, Dorman T, Ratanawongsa N, et al. Effectiveness of Continuing Medical Education. Evidence Report/Technology Assessment No. 149 (Prepared by the Johns Hopkins Evidence-based Practice Center, under Contract No. 290-02-0018.) AHRQ Publication No. 07-E006. Rockville, MD. Agency for Healthcare Research and Quality. January. 2007. Available at: http://www.ahrq.gov/downloads/pub/aevidence/pdf/cme.pdf.
2 Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193):1896-1900. [pmid: 10584742].