# Additional Tables Relevant to Question 2

Table C1 Randomized controlled trials comparing two or more conventional heart valves for valve replacement

Study and status vis-à-vis systematic reviews | Population and follow-up | Valve location and valve comparisons | Outcomes reported | Notes
Aklog, Carr-White, Birks, et al., 2000^1^ Systematic review citation?: No | N: 182 Adult only?: Mixed Follow-up timing: (median) 33.9 mo | Valve position: Aortic Valve 1: Pulmonary autograft Valve 2: Aortic homograft | Hemodynamic: Yes Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes
Ali, Halstead, Cafferty, et al., 2006^2^ and Ali, Halstead, Cafferty, et al., 2007^3^ Systematic review citation?: Yes | N: 161 Adult only?: Yes Follow-up timing: (mean or longest value given) 23 mo | Valve position: Aortic Valve 1: Carpentier- Edwards Perimount Valve 2: Edwards Prima Plus | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: NR Adverse Events: Yes
Angell, Angell, & Sywak, 1977^4^ Systematic review citation?: No | N: 99 Adult only?: NR Follow-up timing: (mean or longest value given) 60 mo | Valve position: Aortic and mitral Valve 1: Starr-Edwards composite-seat (6320 mitral; 2310 aortic) Valve 2: Homografts provided by Northern California Transplant Bank (fresh human aortic valves) | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse Events: Yes
Anonymous, 1985^5^ and Hammermeister, Henderson, Burchfiel, et al., 1987^6^ and Khuri, Folland, Sethi, et al., 1988^7^ and Hammermeister, Sethi, Henderson, et al., 1993^8^ and Hammermeister, Sethi, Henderson, et al., 2000^9^ Systematic review citation?: Yes | N: 575 Adult only?: Yes Follow-up timing: (mean or longest value given) 180 mo | Valve position: Aortic = 394 Mitral = 181 Valve 1: Bjork-Shiley spherical disc Valve 2: Hancock porcine-heterograft bioprosthetic | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse Events: Yes | VA Cooperative Study
Autschbach, Walther, Falk, et al., 2000^10^ Systematic review citation?: No | N: 300 Adult only?: Yes Follow-up timing: (mean or longest value given) 12 mo | Valve position: Aortic Valve 1: ATS Medical, Inc. Valve 2: Carbomedics | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes
Bakhtiary, Abolmaali, Dzemali, et al., 2006^11^ Systematic review citation?: Yes | N: 40 Adult only?: NR Follow-up timing: (mean or longest value given) 5 days | Valve position: Aortic Valve 1: Medtronic Hall tilting disc OR Medtronic ADVANTAGE bileaflet Valve 2: Medtronic Mosaic OR Medtronic Freestyle | Hemodynamic: Yes Cardiac function: NR Mortality: NR Clinical: NR Reoperation: NR Adverse Events: NR | Data from abstract only. Patient population may overlap with that in Bakhtiary, Schiemann, Dzemali, et al., 2006,^12^ but unable to verify.
Bakhtiary, Schiemann, Dzemali, et al., 2006^12^ Systematic review citation?: No | N: 24 Adult only?: Yes Follow-up timing: (mean or longest value given) 6 mo | Valve position: Aortic Valve 1: Medtronic Freestyle Valve 2: Medtronic Mosaic | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: NR Adverse Events: Yes | Patient population may overlap with that in Bakhtiary, Abolmaali, Dzemali, et al., 2006,^11^ but unable to verify.
Berg, McLaughlin, Akar, et al., 1998^13^ Systematic review citation?: No | N: 40 Adult only?: Yes Follow-up timing: (mean or longest value given) 6 mo | Valve position: Aortic Valve 1: Carpentier- Edwards SAV stented bioprosthesis Valve 2: St. Jude Medical Toronto Stentless Porcine Valve | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: NR Adverse Events: Yes
Bloomfield, Kitchin, Wheatley, et al., 1986^14^ and Bloomfield, Wheatley, Prescott, et al., 1991^15^ and Oxenham, Bloomfield, Wheatley, et al., 2003^16^ Systematic review citation?: Yes | N: 541 Adult only?: Yes Follow-up timing: (mean or longest value given) 240 mo | Valve position: Aortic = 211 Mitral = 262 Both = 60 Assoc. tricuspid = 8 Valve 1: Bjork-Shiley ABP/MBRP-60° spherical stilting disc Valve 2: Hancock 242/342 OR later Carpentier-Edwards 2625/6625 | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes
Carr-White, Glennan, Edwards, et al., 1999^17^ Systematic review citation?: No | N: 47 Adult only?: Mixed Follow-up timing: (mean or longest value given) 12 mo | Valve position: Aortic Valve 1: Pulmonary autograft Valve 2: Aortic homograft | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes
Chambers, Rimington, Hodson, et al., 2006^18^ Systematic review citation?: Yes | N: 160 Adult only?: Yes Follow-up timing: (mean or longest value given) 12 mo | Valve position: Aortic Valve 1: St. Jude Medical Toronto Stentless Porcine Valve Valve 2: Edwards Perimount | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: NR Adverse Events: Yes
Chambers, Rimington, Rajani, et al., 2007^19^ Systematic review citation?: No | N: 78 Adult only?: Yes Follow-up timing: (mean or longest value given) 12 mo | Valve position: Aortic Valve 1: Cryolife O‘Brien model 300 Valve 2: St. Jude Medical Stentless Porcine Valve | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: NR Adverse Events: Yes
Chambers, Roxburgh, Blauth, et al., 2005^20^ Systematic review citation?: No | N: 52 Adult only?: Yes Follow-up timing: (mean or longest value given) 12 mo | Valve position: Aortic Valve 1: CarboMedics Top Hat Supraanular Valve 2: Medical Carbon Research Institute (MCRI) On-X | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: NR Adverse Events: Yes
Cohen, Christakis, Campbell, et al., 2002^21^ Systematic review citation?: Yes | N: 99 Adult only?: Yes Follow-up timing: (mean or longest value given) 12 mo | Valve position: Aortic Valve 1: Carpentier- Edwards pericardial Valve 2: St. Jude Medical Toronto Stentless Porcine Valve | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes
Dalmau, Gonzalez- Santos, Lopez- Rodriguez, et al., 2007^22^ Systematic review citation?: No | N: 86 Adult only?: Yes Follow-up timing: (mean or longest value given) 12 mo | Valve position: Aortic Valve 1: Edwards Perimount Magna Valve 2: Medtronic Mosaic | Hemodynamic: Yes Cardiac function: Yes Mortality: NR Clinical: NR Reoperation: NR Adverse Events: NR
de la Fuente, Sanchez, Romero, et al., 2000^23^ Systematic review citation?: No | N: 200 Adult only?: Yes Follow-up timing: (mean or longest value given) 67 mo | Valve position: Aortic Valve 1: CarboMedics mechanical Valve 2: Monostrut mechanical tilting disc | Hemodynamic: NR Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: NR Adverse Events: Yes
Doss, Martens, Wood, et al., 2002^24^ Systematic review citation?: Yes | N: 40 Adult only?: Yes Follow-up timing: (mean or longest value given) 12 mo | Valve position: Aortic Valve 1: Carpentier- Edwards Perimount Valve 2: Edwards Prima Plus | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes | Completely different population than in Doss, Wood, Martens, et al., 2005^25^
Doss, Wood, Martens, et al., 2005^25^ Systematic review citation?: No | N: 40 Adult only?: Yes Follow-up timing: (mean or longest value given) 12 mo | Valve position: Aortic Valve 1: Pulmonary autograft Valve 2: Edwards MIRA | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: Yes Adverse Events: Yes | Completely different population than in Doss Martens, Wood, et al., 2002^24^
Dunning, Graham, Thambyrajah, et al., 2007^26^ Systematic review citation?: No | N: 60 Adult only?: Yes Follow-up timing: (mean or longest value given) 12 mo | Valve position: Aortic Valve 1: Sorin Freedom Valve 2: Sorin More | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: NR Adverse Events: Yes
Efskind, Nitter- Hauge, Hall, et al., 1973^27^ Systematic review citation?: No | N: 115 Adult only?: NR Follow-up timing: (mean or longest value given) 18 30 mo | Valve position: Aortic = 68 Mitral = 47 Valve 1: Lillehei-Kaster low profile Valve 2: Bjork-Shiley low profile | Hemodynamic: NR Cardiac function: Yes Mortality: NR Clinical: Yes Reoperation: Yes Adverse Events: NR
Eichinger, Botzenhardt, Keithahn, et al., 2004^28^ and Eichinger, Botzenhardt, Guenzinger, et al., 2004^29^ Systematic review citation?: No | N: 136 Adult only?: Yes Follow-up timing: (mean or longest value given) 10 mo | Valve position: Aortic Valve 1: Medtronic Mosaic Valve 2: Carpentier- Edwards Perimount | Hemodynamic: Yes Cardiac function: Yes Mortality: NR Clinical: NR Reoperation: NR Adverse Events: NR
Fiore, Barner, Swartz, et al., 1998^30^ Systematic review citation?: No | N: 156 Adult only?: Yes Follow-up timing: (mean or longest value given) 61 mo | Valve position: Mitral Valve 1: St. Jude Medical bileaflet Valve 2: Medtronic Hall tilting disc | Hemodynamic: Yes Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes
Fiore, Swartz, Grunkmeier, et al., 1997^31^ Systematic review citation?: No | N: 80 Adult only?: Yes Follow-up timing: (mean or longest value given) 40.5 mo | Valve position: Aortic Valve 1: St. Jude Medical bileaflet Valve 2: Medtronic Hall tilting disc | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: NR Adverse Events: Yes | Subgroup population analysis from a 456- patient RCT
Graham, Thambyrajah, Stewart, et al., 2005^32^ Systematic review citation?: Yes | N: 54 Adult only?: Yes Follow-up timing: (mean or longest value given) 6 mo | Valve position: Aortic Valve 1: Sorin Freedom stentless Valve 2: Sorin More stented | Hemodynamic: Yes Cardiac function: Yes Mortality: NR Clinical: NR Reoperation: NR Adverse Events: NR | Data from abstract only
Gross, Harringer, Mair, et al., 1995^33^ and Gross, Harringer, Beran, et al., 1999^34^ Systematic review citation?: No | N: 139 Adult only?: Yes Follow-up timing: (mean or longest value given) 45 mo | Valve position: Aortic Valve 1: Cryopreserved homograft Valve 2: Edwards Prima stentless model 2500 | Hemodynamic: Yes Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse Events: Yes
Guenzinger, Eichinger, Hettich, et al., 2008^35^ Systematic review citation?: No | N: 80 Adult only?: Yes Follow-up timing: (mean or longest value given) 6 mo | Valve position: Aortic Valve 1: Medtronic Advantage Supra Valve 2: St. Jude Medical Regent | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: NR Adverse Events: es
Horstkotte, Haerten, Herzer, et al., 1983^36^ Systematic review citation?: Yes | N: 150 Adult only?: Mixed Follow-up timing: (mean or longest value given) 60 mo | Valve position: Mitral Valve 1: Bjork-Shiley standard Valve 2: Lillehei-Kaster Valve 3: Starr-Edwards 6120 | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes
Jasinski, Ulbrych, Kolowca, et al., 2004^37^ Systematic review citation?: Yes | N: 16 Adult only?: Yes Follow-up timing: (mean or longest value given) 1 mo | Valve position: Aortic Valve 1: Medtronic Mosaic Valve 2: Medtronic Freestyle | Hemodynamic: NR Cardiac function: Yes Mortality: NR Clinical: NR Reoperation: NR Adverse Events: NR
John, Khan, Kuo, et al., 2006^38^ Systematic review citation?: No | N: 242 Adult only?: NR Follow-up timing: (mean or longest value given) 40 mo | Valve position: Aortic Valve 1: Medtronic Mosaic Valve 2: Carpentier- Edwards SAV porcine bioprosthesis | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes | Data from abstract only
Kim, Lesaffre, Scheys, et al., 1994^39^ Systematic review citation?: No | N: 403 Adult only?: Yes Follow-up timing: (mean or longest value given) 61 mo | Valve position: Aortic and mitral Valve 1: Monostrut tilting disc Valve 2: Medtronic-Hall tilting disc | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes
Kleine, Hasenkam, Nygaard, et al., 2000^40^ Systematic review citation?: No | N: 24 Adult only?: Yes Follow-up timing: (mean or longest value given) 6 mo | Valve position: Aortic Valve 1: Medtronic-Hall tilting disc Valve 2: St. Jude Medical bileaflet | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: NR Adverse Events: Yes
Kuntze, Blackstone, and Ebels, 1998^41^ and Kuntze, Ebels, Eijgelaar, et al, 1989^42^ Systematic review citation?: No | N: 419 Adult only?: Yes Follow-up timing: (median) 98.5 mo | Valve position: Aortic = 254 Mitral = 111 Both = 54 Valve 1: Bjork-Shiley Convex-Concave (later replaced by Bjork-Shiley Monostrut) Valve 2: Medtronic-Hall Valve 3: Edwards- Duromedics bileaflet | Hemodynamic: NR Cardiac function: NR Mortality: No Clinical: NR Reoperation: NR Adverse Events: Yes | Edwards-Duromedics was added as a third arm after approx 2.5 years – therefore shorter follow-up and smaller n
Kvidal, Bergstrom, Malm, et al., 2000^43^ Systematic review citation?: No | N: 424 Adult only?: Yes Follow-up timing: (mean or longest value given) 120 mo | Valve position: Aortic Valve 1: Bjork-Shiley Monostrut Valve 2: Edwards Duromedics | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse Events: Yes
Lehmann, Walther, Kempfert, et al., 2007^44^ Systematic review citation?: No | N: 223 Adult only?: Yes Follow-up timing: (mean or longest value given) 94.2 mo | Valve position: Aortic Valve 1: Medtronic Freestyle OR St. Jude Toronto Stentless Porcine Valve Valve 2: Carpentier- Edwards porcine xenograft | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: No Adverse Events: Yes
Levang, 1978^45^ and Levang, 1979^46^ and Levang, Nitter- Hauge, Levorstad, et al., 1979^47^ and Levang, Levorstad, Jaugland, 1980^48^ Systematic review citation?: No | N: 300 Adult only?: Yes Follow-up timing: (mean or longest value given) 24 mo | Valve position: Aortic Valve 1: Bjork-Shiley Valve 2: Lillehei-Kaster | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: NR Adverse Events: NR
Lim, Caputo, Ascione, et al., 2002^49^ and Bryan, Rodgers, Bayliss, et al., 2007^50^ Systematic review citation?: No | N: 485 Adult only?: Yes Follow-up timing: (mean or longest value given) 120 mo | Valve position: Aortic = 288 Mitral = 160 Both = 37 Valve 1: CarboMedics bileaflet mechanical Valve 2: St. Jude bileaflet mechanical | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes
Lundblad, Hagen, Smith, et al., 2001^51^ Systematic review citation?: No | N: 17 Adult only?: Yes Follow-up timing: (mean or longest value given) 3 mo | Valve position: Aortic Valve 1: CarboMedics Top Hat Supraannular Valve 2: CarboMedics Intraannular valve | Hemodynamic: Yes Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: NR Adverse Events: Yes
Maselli, Pizio, Pasquale, et al., 1999^52^ Systematic review citation?: Yes | N: 40 Adult only?: Yes Follow-up timing: (mean or longest value given) 8 mo | Valve position: Aortic Valve 1: Aortic homograft Valve 2: St. Jude Medical Toronto Stentless Porcine Valve Valve 3: Medtronic Freestyle Valve 4: Medtronic Intact | Hemodynamic: Yes Cardiac function: Yes Mortality: NR Clinical: Yes Reoperation: NR Adverse Events: NR
Melina, DeRoebrts, Gaer, et al., 2004^53^ and Meline, Mitchell, Amrani, et al., 2002^54^ Systematic review citation?: No | N: 147 Adult only?: Yes Follow-up timing: (mean or longest value given) 45 mo | Valve position: Aortic Valve 1: Medtronic Freestyle Valve 2: Homograft | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes
Mikaeloff, Jegasen, Ferrini, et al., 1989^55^ Systematic review citation?: No | N: 357 Adult only?: Yes Follow-up timing: (mean or longest value given) 64.7 mo | Valve position: Mitral Valve 1: St. Jude Medical prosthesis Valve 2: Bjork-Shiley valve OR Starr-Edwards 6120 valve | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes
Miraldi, Spagnesi, Tallarico, et al., 2006^56^ Systematic review citation?: No | N: 80 Adult only?: Yes Follow-up timing: (mean or longest value given) 12 mo | Valve position: Aortic Valve 1: Carpentier- Edwards Perimount Valve 2: Sorin Freedom | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: NR Adverse Events: Yes | Small aortic annulus
Murday, Hochstitzky, Mansfield, et al., 2003^57^ Systematic review citation?: No | N: 389 Adult only?: Yes Follow-up timing: (mean or longest value given) 96 mo | Valve position: Aortic = 267 Mitral = 122 Valve 1: St. Jude Medical mechanical Valve 2: Starr-Edwards | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes
Otero, Pomar, Revuelta, et al., 2005^58^ Systematic review citation?: No | N: 80 Adult only?: Yes Follow-up timing: (mean or longest value given) 12 mo | Valve position: Aortic Valve 1: Sorin Slimline Valve 2: St. Jude Medical High Performance | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: NR Adverse Events: Yes | Small aortic annulus
Perez de Arenaza, Lees, Flather, et al., 2005^59^ Systematic review citation?: Yes | N: 190 Adult only?: Yes Follow-up timing: (mean or longest value given) 12 mo | Valve position: Aortic Valve 1: Medtronic Freestyle Valve 2: Medtronic Mosaic | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes
Rostad, Simonsen, and Nitter-Hauge, 1979^60^ Systematic review citation?: No | N: 48 Adult only?: Yes Follow-up timing: (mean or longest value given) 27 mo | Valve position: Aortic and mitral Valve 1: Bjork-Shiley Valve 2: Lillehei-Kaster | Hemodynamic: Yes Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: NR Adverse Events: Yes
Santini, Bertolini, Montalbano, et al., 1998^61^ Systematic review citation?: Yes | N: 77 Adult only?: Yes Follow-up timing: (mean or longest value given) 14.5 – 18.5 mo | Valve position: Aortic Valve 1: Hancock II porcine Valve 2: St. Jude Medical Toronto Stentless Porcine Valve OR Biocor stentless | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: NR Adverse Events: Yes
Santini, Dyke, Edwards, et al., 1997^62^ Systematic review citation?: No | N: 70 Adult only?: mixed Follow-up timing: (mean or longest value given) 16 mo | Valve position: Aortic Valve 1: Aortic homograft Valve 2: Pulmonary autograft | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: NR Adverse Events: NR
Schaff, Carrell, Steckelberg, et al., 1999^63^ and Schaff, Carrell, Jamieson et al., 2002^64^ and Englberger, Schaff, Jamieson, et al. 2005^65^ and Grunkemeier, Jin, Im, et al., 2006^66^ Systematic review citation?: No | N: 807 Adult only?: Yes Follow-up timing: (mean or longest value given) 54 mo | Valve position: Aortic = 476 Mitral = 258 Both = 73 Valve 1: St. Jude Medical Silzone-coated prosthesis Valve 2: St. Jude Medical mechanical | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse Events: Yes | AVERT trial
Seitelberger, Bialy, Gottardi, et al., 2004^67^ Systematic review citation?: No | N: 86 Adult only?: Yes Follow-up timing: (mean or longest value given) 6 mo | Valve position: Aortic Valve 1: Edwards Lifescience pericardial Valve 2: Medtronic Mosaic | Hemodynamic: Yes Cardiac function: Yes Mortality: NR Clinical: Yes Reoperation: NR Adverse Events: NR
Sensky, Loubani, Keal, et al., 2003^68^ Systematic review citation?: No | N: 56 Adult only?: Yes Follow-up timing: (mean or longest value given) 6 mo | Valve position: Aortic Valve 1: ATS Medical bileaflet OR Ultracor tilting disc Valve 2: Carpentier- Edwards Perimount | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: NR Adverse Events: NR
Totaro, Degno, Zaidi, et al., 2005^69^ Systematic review citation?: Yes | N: 63 Adult only?: Yes Follow-up timing: (mean or longest value given) 1 mo | Valve position: Aortic Valve 1: Carpentier- Edwards Perimount Magna Valve 2: Carpentier- Edwards Perimount | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: NR Adverse Events: NR
Vitale, Caldarera, Muneretto, et al., 2001^70^ Systematic review citation?: No | N: 140 Adult only?: Yes Follow-up timing: (mean or longest value given) 6 mo | Valve position: Aortic Valve 1: St. Jude Medical Hemodynamic Plus Valve 2: St. Jude Medical standard cuff | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: Yes Adverse Events: Yes
Walther, Falk, Langebartels, et al., 1999^71^ and Walther, Falk, Langebartels, et al., 1999^72^ Systematic review citation?: Yes | N: 180 Adult only?: Yes Follow-up timing: (mean or longest value given) 6 mo | Valve position: Aortic Valve 1: Medtronic Freestyle OR St. Jude Medical Toronto Stentless Porcine Valve Valve 2: Carpentier- Edwards porcine | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: NR Adverse Events: Yes
Walther, Lehmann, Falk, et al., 2004^73^ Systematic review citation?: No | N: 100 Adult only?: Yes Follow-up timing: (mean or longest value given) 14.6 mo | Valve position: Aortic Valve 1: Medtronic Mosaic Valve 2: Edwards Lifesciences Perimount | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: NR Adverse Events: NR
Wheatley, Tolland, Pathi, et al., 1995^74^ and Chaudry, Raco, Murithi, et al., 2000^75^ Systematic review citation?: No | N: 170 Adult only?: Yes Follow-up timing: (mean or longest value given) 98 mo | Valve position: Aortic = 94 Mitral = 54 Both = 22 Valve 1: Bioflo pericardial bioprosthesis Valve 2: Carpentier- Edwards Supraannular porcine bioprosthesis | Hemodynamic: Yes Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: Yes Adverse Events: Yes
Williams, Muir, Pathi, et al., 1999^76^ Systematic review citation?: Yes | N: 40 Adult only?: NR Follow-up timing: (mean or longest value given) 32 mo | Valve position: Aortic Valve 1: St. Jude Medical Toronto Stentless Porcine Valve stentless Valve 2: Carpentier- Edwards SAV | Hemodynamic: Yes Cardiac function: Yes Mortality: NR Clinical: NR Reoperation: NR Adverse Events: NR | Data from abstract
Wiseth, Haaverstad, Vitale, et al., 2005^77^ Systematic review citation?: No | N: 20 Adult only?: NR Follow-up timing: (mean or longest value given) 6 mo | Valve position: Aortic Valve 1: CarboMedics Reduced bileaflet Valve 2: Medtronic Hall | Hemodynamic: Yes Cardiac function: NR Mortality: NR Clinical: NR Reoperation: NR Adverse Events: NR | Data from abstract only

Table C2 Observational studies comparing two or more conventional heart valves for valve replacement

Study and status vis-à-vis systematic reviews | Population and follow-up | Valve location and valve comparisons | Outcomes reported | Notes
Akins, Hilgenberg, Vlahakes, et al., 2002^78^ Systematic review citation?: Yes | N: 750 Adult only?: Yes Follow-up timing: (mean) 68 mo | Valve position: Aortic Valve 1: Bioprosthetic (Carpentier-Edwards porcine, Carpentier- Edwards pericardial) Valve 2: Mechanical (St. Jude Medical, Medtronic Hall, Starr-Edwards, Bjork-Shiley, CarboMedics) | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes
Bernet, Bakut, Grize, et al., 2007^79^ Systematic review citation?: No | N: 1161 Adult only?: NR Follow-up timing: (mean or longest value given) 55 mo | Valve position: NR Valve 1: St. Jude Medical Valve 2: ATS Medical mechanical | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: NR Adverse events: Yes | Data from abstract only
Bleiziffer, Eichinger, Wagner, et al., 2005^80^ Systematic review citation?: Yes | N: 40 Adult only?: Yes Follow-up timing: (mean or longest value given) 24 mo | Valve position: Aortic Valve 1: St. Jude Medical Toronto Root Valve 2: Medtronic Mosaic | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: NR Adverse events: NR
Borger, Carson, Ivanov, et al., 2005^81^ Systematic review citation?: Yes | N: 737 Adult only?: Yes Follow-up timing: (mean or longest value given) 79 mo | Valve position: Aortic Valve 1: St. Jude Medical Toronto Stentless Porcine Valve OR Medtronic Freestyle Valve 2: Carpentier- Edwards Perimount OR Medtronic Mosaic | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: NR Adverse events: Yes
Bottio, Rizzoli, Caprili, et al., 2005^82^ Systematic review citation?: No | N: 379 Adult only?: Yes Follow-up timing: (mean) Sorin = 180 mo Hancock = 158 mo | Valve position: Aortic Valve 1: Sorin Monocast Valve 2: Hancock standard | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes | Data from abstract only
Bove, Belleghem, Francois, et al., 2006^83^ Systematic review citation?: Yes | N: 255 Adult only?: Yes Follow-up timing: 12 to 136 mo | Valve position: Aortic Valve 1: St. Jude Medical Toronto Stentless Porcine Valve Valve 2: Carpentier- Edwards Perimount | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: NR Adverse events: Yes
Carrier, Hebert, Pellerin, et al., 2003^84^ Systematic review citation?: Yes | N: 97 Adult only?: Yes Follow-up timing: (mean or longest value given) 60 mo | Valve position: Tricuspid Valve 1: Carpentier- Edwards pericardial bioprosthetic Valve 2: Bileaflet mechanical (CarboMedics AND St. Jude Medical) | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: NR
Dalrymple-Hay, Leung, Ohri, et al., 1999^85^ Systematic review citation?: Yes | N: 87 Adult only?: mixed Follow-up timing: (mean or longest value given) 97 mo | Valve position: Tricuspid and/or aortic Valve 1: Tissue Valve 2: Mechanical | Hemodynamic: NR/ Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes
de la Fuente, Sanchez, Imizcoz, et al., 2003^86^ Systematic review citation?: Yes | N: 215 Adult only?: Yes Follow-up timing: (mean or longest value given) 72 mo | Valve position: Aortic Valve 1: Medtronic Intact Valve 2: Carpentier- Edwards SAV | Hemodynamic: Yes Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: Yes Adverse events: Yes
Del Rizzo and Abdoh, 1998^87^ Systematic review citation?: No | N: 995 Adult only?: Yes Follow-up timing: (mean or longest value given) 36 mo | Valve position: Aortic Valve 1: St. Jude Medical Toronto Stentless Porcine Valve Valve 2: Medtronic Freestyle | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: NR Adverse events: Yes
Do, Pellerin, Carrier, et al., 2000^88^ Systematic review citation?: Yes | N: 29 Adult only?: Yes Follow-up timing: (mean) 70 ± 64 mo | Valve position: Tricuspid Valve 1: Bileaflet mechanical Valve 2: Bioprosthetic valve | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: NR Adverse events: Yes
Eberlein, von der Emde, Rein, et al., 1990^89^ Systematic review citation?: Yes | N: 1668 Adult only?: mixed Follow-up timing: (mean) 77 mo | Valve position: Mitral Valve 1: Starr-Edwards model 6520 Valve 2: Bjork-Shiley plane prosthesis Valve 3: Bjork-Shiley convexo-concave 60º Valve 4: St. Jude Medical Valve 5: Carpentier- Edwards tissue | Hemodynamic: NR Cardiac function: NR Mortality: NR Clinical: NR Reoperation: NR Adverse events: Yes
Hayashi, Saito, Yamamoto, et al., 1996^90^ Systematic review citation?: Yes | N: 29 Adult only?: mixed Follow-up timing: (mean or longest value given) 80 mo | Valve position: Tricuspid Valve 1: Carpentier- Edwards porcine Valve 2: St. Jude Medical | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: NR Adverse events: Yes
Houel, Le Besnerais, Soustelle, et al.,91 Systematic review citation?: Yes | N: 212 Adult only?: Yes Follow-up timing: (mean or longest value given) 98 to 118 mo | Valve position: Aortic Valve 1: Carpentier- Edwards standard porcine Valve 2: Mitroflow pericardial | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes
Jamieson, von Lipinski, Mitagishima, et al., 2005^92^ Systematic review citation?: No | N: 1782 Adult only?: Yes Follow-up timing: (mean or longest value given) 180 mo | Valve position: Mitral Valve 1: Bioprosthesis (Carpentier-Edwards SAV, Carpentier- Edwards Perimount, Medtronic Mosaic) Valve 2: Mechanical (St. Jude Medical, CarboMedics) | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes
Jasinski, Hayton, Kadziola, et al., 2002^93^ Systematic review citation?: Yes | N: 28 Adult only?: Yes Follow-up timing: (mean or longest value given) 1**2 mo | Valve position: Aortic Valve 1: Medtronic Mosaic Valve 2: Medtronic Freestyle | Hemodynamic: Yes Cardiac function: Yes Mortality: NR Clinical: NR Reoperation: NR Adverse events: NR
Jin, Zhang, Gibson, et al., 1996^94^ Systematic review citation?: Yes | N: 137 Adult only?: Yes Follow-up timing: (mean or longest value given) 36 mo | Valve position: Aortic Valve 1: Aortic homograft Valve 2: St. Jude Medical Toronto Stentless Porcine Valve Valve 3: Carpentier- Edwards porcine OR St. Jude Medical bileaflet | Hemodynamic: Yes Cardiac function: Yes Mortality: NR Clinical: NR Reoperation: NR Adverse events: NR
Kaplan, Kut, Demirtas, et al., 2002^95^ Systematic review citation?: Yes | N: 122 Adult only?: mixed Follow-up timing: (mean or longest value given) 228 mo | Valve position: Tricuspid Valve 1: Mechanical (St. Jude Medical, CarboMedics, Medtronic, Sorin, Bjork-Shiley, Hall- Kaster, Omniscience) Valve 2: Bioprosthetic (Biocor porcine, Wessex Medical porcine, Medtronic Hancock, Carpentier-Edwards, Ionescu-Shiley bovine) | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes
Kulik, Bedard, Lam, et al., 2006^96^ Systematic review citation?: No | N: 659 Adult only?: Yes Follow-up timing: (mean) AVR = 59 mo MVR = 66 mo | Valve position: Aortic and/or mitral Valve 1: Mechanical (Medtronic-Hall, St. Jude Medical, CarboMedics, MCRI On-X) Valve 2: Bioprosthetic (homograft, Medtronic Hancock, Edwards pericardial) | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes
Kurlansky, Williams, Traad, et al., 2006^97^ Systematic review citation?: No | N: 1104 Adult only?: Yes Follow-up timing: (mean or longest value given) 64 mo | Valve position: Aortic = 703 Mitral = 488 Tricuspid = 5 Pulmonic = 1 (93 pts had multi-valve procedures) Valve 1: Carpentier- Edwards porcine Valve 2: St. Jude Medical | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: NR Adverse events: NR
Le Tourneau, Savoye, McFadden, et al., 1999^98^ Systematic review citation?: Yes | N: 162 Adult only?: Yes Follow-up timing: (mean or longest value given) 53 to 58 mo | Valve position: Aortic Valve 1: Sorin Pericarbon model SA Valve 2: Carpentier- Edwards model 2900 | Hemodynamic: Yes Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: Yes Adverse events: Yes
Le Tourneau, Vinventelli, Fayad, et al., 2002^99^ Systematic review citation?: Yes | N: 150 Adult only?: Yes Follow-up timing: (mean) 78 mo | Valve position: Aortic Valve 1: Carpentier- Edwards Supraannular model 2650 Valve 2: Carpentier- Edwards pericardial model 2900 | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: Yes Reoperation: Yes Adverse events: Yes
Milano, Guglielmi, Carlo, et al., 1998^100^ Systematic review citation?: Yes | N: 355 Adult only?: Yes Follow-up timing: (mean or longest value given) 120 mo | Valve position: Aortic Valve 1: Mechanical (St. Jude Medical valve, St. Jude Medical HP, Sorin Bicarbon, CarboMedics, Duromedics) Valve 2: Biological (Carpentier-Edwards standard porcine, Medtronic Hancock II, Edwards-Prima, St. Jude Medical X-cell, Medtronic Mosaic | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes
Munro, Jamieson, Tyers, et al., 1995^101^ Systematic review citation?: Yes | N: 94 Adult only?: Yes Follow-up timing: (mean or longest value given) 44 mo | Valve position: Tricuspid Valve 1: Bioprosthetic Valve 2: Mechanical | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes
Ninet, Tronc, Robin, et al., 1998^102^ Systematic review citation?: Yes | N: 206 Adult only?: Yes Follow-up timing: (mean) Valve 1 = 53 mo Valve 2 = 64 mo | Valve position: Aortic Valve 1: St. Jude Medical Valve 2: Mitroflow pericardial | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: Yes Adverse events: Yes
Peterseim, Cen, Cheruvu, et al., 1999^103^ Systematic review citation?: Yes | N: 841 Adult only?: Yes Follow-up timing: (mean or longest value given) 120 mo | Valve position: Aortic Valve 1: St. Jude Medical model A102 Valve 2: Carpentier- Edwards model 2625 | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes
Prasongsukam, Jamieson, Lichtenstin, 2005^104^ Systematic review citation?: No | N: 1587 Adult only?: Yes Follow-up timing: (mean or longest value given) 144 to 189 mo | Valve position: Aortic or mitral Valve 1: Bioprosthetic Valve 2: Mechanical | Hemodynamic: NR Cardiac function: NR Mortality: NR Clinical: NR Reoperation: Yes Adverse events: Yes | Data from abstract only
Ratnatunga, Edwards, Dore, et al., 1998^105^ Systematic review citation?: Yes | N: 425 Adult only?: Yes Follow-up timing: (mean or longest value given) 120 mo | Valve position: Tricuspid Valve 1: Biological Valve 2: Mechanical | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: NR
Rizzoli, Vendramin, Nesseris, et al., 2004^106^ Systematic review citation?: No | N: 101 Adult only?: Yes Follow-up timing: (mean or longest value given) 89 mo | Valve position: Tricuspid Valve 1: Bioprosthesis Valve 2: Mechanical | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: NR
Ruel, Chan, Bedard, et al., 2007^107^ Systematic review citation?: No | N: 567 Adult only?: Yes Follow-up timing: (mean or longest value given) 240 mo | Valve position: Aortic = 314 Mitral = 214 Both = 39 Valve 1: Mechanical (Bjork-Shiley, CarboMedics, Harken, Lillehei-Kaster, Medtronic-Hall, Starr- Edwards, St. Jude Medical) Valve 2: Bioprosthesis (Carpentier-Edwards, homograft, Ionescu- Shiley, Medtronic Hancock) | Hemodynamic: NR/ Cardiac function: NR Mortality: NR Clinical: NR Reoperation: Yes Adverse events: Yes
Schelbert, Vaughan- Sarrazin, Welke, et al., 2008^108^ Systematic review citation?: No | N: 307,054 Adult only?: Yes Follow-up timing: (range) 8 to 158 mo | Valve position: Aortic Valve 1: Bioprosthesis Valve 2: Mechanical | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes
Scully and Armstrong, 1995^109^ Systematic review citation?: Yes | N: 60 Adult only?: Yes Follow-up timing: (mean) 75 mo | Valve position: Tricuspid Valve 1: Bioprosthetic (Medtronic Hancock II, Carpentier-Edwards porcine, Ionescu-Shiley pericardial, Medtronic Intact, Medtronic Hancock) Valve 2: Mechanical (Bjork-Shiley Monostrut, Bjork-Shiley welded outlet strut 60º or 70º, St. Jude Medical bileaflet) | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: Yes Reoperation: Yes Adverse events: Yes
Smedira, Blackstone, Roselli, et al., 2006^110^ Systematic review citation?: No | N: 1222 Adult only?: Yes Follow-up timing: (mean) Pericardial = 180 mo Allograft = 67 mo | Valve position: Aortic Valve 1: Stented bovine pericardial Valve 2: Cryopreserved allograft | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: NR
Tsialtas, Bolognesi, Beghi, et al., 2007^111^ Systematic review citation?: Yes | N: 68 Adult only?: Yes Follow-up timing: (mean or longest value given) 12 mo | Valve position: Aortic Valve 1: Carpentier- Edwards Perimount Valve 2: St. Jude Medical Toronto Stentless Porcine Valve OR Shelhigh Super Stentless | Hemodynamic: Yes Cardiac function: Yes Mortality: Yes Clinical: NR Reoperation: NR Adverse events: NR
Valfre, Rizzoli, Zussa, et al., 2006^112^ Systematic review citation?: No | N: 1931 Adult only?: Yes Follow-up timing: (median) 144 mo | Valve position: Aortic and mitral Valve 1: Medtronic Hancock Valve 2: Medtronic Hancock II | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes
Van Nooten, Caes, Taeymans, et al., 1995^113^ Systematic review citation?: Yes | N: 146 Adult only?: Yes Follow-up timing: (mean or longest value given) 30 mo | Valve position: Tricuspid Valve 1: Bioprosthetic (Carpentier-Edwards porcine & bovine, Medtronic Hancock, CarboMedics Mitroflow) Valve 2: Mechanical (Smeloff-Cutter, Kay- Shiley, DeBakey, Bjork- Shiley tilting disc, St. Jude Medical) | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes
Vitale, De Feo, Siena, et al., 2004^114^ Systematic review citation?: Yes | N: 2734 Adult only?: Yes Follow-up timing: (mean or longest value given) 49 to 114 mo | Valve position: Aortic Valve 1: Tilting disc (Bjork-Shiley, Medtronic- Hall, Sorin Monodisc standard, Sorin Monodisc Allcarbon, Sorin Monodisc Carbocast Ultracor) Valve 2: Bileaflet (Aortec, ATS Medical, CarboMedics, CarboMedics TH, Edwards, Duromedics, Edwards TEKNA, Edwards Mira, Onyx, St. Jude Medical, St. Jude Medical HP, St. Jude Medical Regent, Sorin Bicarbon) | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes
Westaby, Horton, Jin, et al., 2000^115^ Systematic review citation?: Yes | N: 407 Adult only?: Yes Follow-up timing: (mean or longest value given) 60 mo | Valve position: Aortic Valve 1: Medtronic Freestyle Valve 2: Carpentier- Edwards model 2650 | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes
Westaby, Jonson, Payne, et al., 2001^116^ Systematic review citation?: No | N: 2082 Adult only?: Yes Follow-up timing: (mean or longest value given) 1 mo | Valve position: Aortic/ Valve 1: Medtronic Mosaic Valve 2: Medtronic Freestyle | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: NR Adverse events: NR
Wu, Gregorio, Renzulli, et al., 2004^117^ Systematic review citation?: No | N: 1873 Adult only?: mixed Follow-up timing: (mean) Valve 1 = 139 mo Valve 2 = 54 mo | Valve position: Aortic Valve 1: Single disc (Bjork-Shiley, Medtronic- Hall, Lillehei-Kaster, Omnicarbon, Sorin standard, Sorin Allcarbon, Sorin Carbocast) Valve 2: Bileaflet (ATS- Medical Edwards MIRA, Sorin Bicarbon, CarboMedics standard, CarboMedics HP, Duromedics, Edwards TEKNA, St. Jude Medical standard, St. Jude Medical HP, St. Jude Medical Regent) | Hemodynamic: NR Cardiac function: NR Mortality: Yes Clinical: NR Reoperation: Yes Adverse events: Yes

## References to Appendix C

1 Aklog L, Carr-White GS, Birks EJ, et al. Pulmonary autograft versus aortic homograft for aortic valve replacement: interim results from a prospective randomized trial. J Heart Valve Dis. 2000;9(2):176-188. discussion 188–189. [pmid: 10772034].
2 Ali A, Halstead JC, Cafferty F, et al. Are stentless valves superior to modern stented valves? A prospective randomized trial. Circulation. 2006;114(1 Suppl):I535-I540. [pmid: 16820633].
3 Ali A, Halstead JC, Cafferty F, et al. Early clinical and hemodynamic outcomes after stented and stentless aortic valve replacement: results from a randomized controlled trial. Ann Thorac Surg. 2007;83(6):2162-2168. [pmid: 17532416].
4 Angell WW, Angell JD, Sywak A. Section of tissue or prosthetic valve. A five-year prospective, randomized comparison. J Thorac Cardiovasc Surg. 1977;73(1):43-53. [pmid: 401529].
5 Prognosis in valvular heart disease. I. Description of purpose, organization, data collection techniques, estimates of statistical power, and criteria for termination of patient entry. VA Cooperative Study Group on Valvular Heart Disease. Control Clin Trials. 1985;6(1):51-74. [pmid: 3987303].
6 Hammermeister KE, Henderson WG, Burchfiel CM, et al. Comparison of outcome after valve replacement with a bioprosthesis versus a mechanical prosthesis: initial 5 year results of a randomized trial. J Am Coll Cardiol. 1987;10(4):719-732. [pmid: 3309002].
7 Khuri SF, Folland ED, Sethi GK, et al. Six month postoperative hemodynamics of the Hancock heterograft and the Bjork-Shiley prosthesis: results of a Veterans Administration cooperative prospective randomized trial. J Am Coll Cardiol. 1988;12(1):8-18. [pmid: 3288680].
8 Hammermeister KE, Sethi GK, Henderson WG, et al. A comparison of outcomes in men 11 years after heart-valve replacement with a mechanical valve or bioprosthesis. Veterans Affairs Cooperative Study on Valvular Heart Disease. N Engl J Med. 1993;328(18):1289-1296. [pmid: 8469251].
9 Hammermeister K, Sethi GK, Henderson WG, et al. Outcomes 15 years after valve replacement with a mechanical versus a bioprosthetic valve: final report of the Veterans Affairs randomized trial. J Am Coll Cardiol. 2000;36(4):1152-1158. [pmid: 11028464].
10 Autschbach R, Walther T, Falk V, et al. Prospectively randomized comparison of different mechanical aortic valves. Circulation. 2000;102:III1-4. [pmid: 11082353].
11 Bakhtiary F, Abolmaali N, Dzemali O, et al. Impact of mechanical and biological aortic valve replacement on coronary perfusion: a prospective, randomized study. J Heart Valve Dis. 2006;15(1):5-11. discussion 11. [pmid: 16480006].
12 Bakhtiary F, Schiemann M, Dzemali O, et al. Stentless bioprostheses improve postoperative coronary flow more than stented prostheses after valve replacement for aortic stenosis. J Thorac Cardiovasc Surg. 2006;131(4):883-888. [pmid: 16580448].
13 Berg GA, McLaughlin KE, Akar R, et al. A three year experience with the Toronto stentless porcine valve. Ann Thorac Cardiovasc Surg. 1998;4(3):138-145. [pmid: 9660911].
14 Bloomfield P, Kitchin AH, Wheatley DJ, et al. A prospective evaluation of the Bjork-Shiley, Hancock, and Carpentier-Edwards heart valve prostheses. Circulation. 1986;73(6):1213-1222. [pmid: 3516447].
15 Bloomfield P, Wheatley DJ, Prescott RJ, et al. Twelve-year comparison of a Bjork-Shiley mechanical heart valve with porcine bioprostheses. N Engl J Med. 1991;324(9):573-579. [pmid: 1992318].
16 Oxenham H, Bloomfield P, Wheatley DJ, et al. Twenty year comparison of a Bjork-Shiley mechanical heart valve with porcine bioprostheses. Heart. 2003;89(7):715-721. [pmid: 12807838].
17 Carr-White GS, Glennan S, Edwards S, et al. Pulmonary autograft versus aortic homograft for rereplacement of the aortic valve: results from a subset of a prospective randomized trial. Circulation. 1999;100:II103-106. [pmid: 10567286].
18 Chambers JB, Rimington HM, Hodson F, et al. The subcoronary Toronto stentless versus supra-annular Perimount stented replacement aortic valve: early clinical and hemodynamic results of a randomized comparison in 160 patients. J Thorac Cardiovasc Surg. 2006;131(4):878-872. [pmid: 16580447].
19 Chambers JB, Rimington HM, Rajani R, et al. A randomized comparison of the Cryolife O’Brien and Toronto stentless replacement aortic valves. J Thorac Cardiovasc Surg. 2007;133(4):1045-1050. [pmid: 17382651].
20 Chambers J, Roxburgh J, Blauth C, et al. A randomized comparison of the MCRI On-X and CarboMedics Top Hat bileaflet mechanical replacement aortic valves: early postoperative hemodynamic function and clinical events. J Thorac Cardiovasc Surg. 2005;130(3):759-764. [pmid: 16153925].
21 Cohen G, Christakis GT, Joyner CD, et al. Are stentless valves hemodynamically superior to stented valves? A prospective randomized trial. Ann Thorac Surg. 2002;73(3):767-775. discussion 775–778. [pmid: 11899180].
22 Dalmau MJ, Maria Gonzalez-Santos J, Lopez-Rodriguez J, et al. One year hemodynamic performance of the Perimount Magna pericardial xenograft and the Medtronic Mosaic bioprosthesis in the aortic position: a prospective randomized study. Interactive Cardiovascular & Thoracic Surgery. 2007;6(3):345-349. [pmid: 17669862].
23 de la Fuente A, Sanchez R, Romero J, et al. CarboMedics and Monostrut valves: clinical and hemodynamic outcomes in a randomized study. J Heart Valve Dis. 2000;9(2):303-307. [pmid: 10772053].
24 Doss M, Martens S, Wood JP, et al. Performance of stentless versus stented aortic valve bioprostheses in the elderly patient: a prospective randomized trial. Eur J Cardiothorac Surg. 2003;23(3):299-304. [pmid: 12614797].
25 Doss M, Wood JP, Martens S, et al. Do pulmonary autografts provide better outcomes than mechanical valves? A prospective randomized trial. Ann Thorac Surg. 2005;80(6):2194-2198. [pmid: 16305870].
26 Dunning J, Graham RJ, Thambyrajah J, et al. Stentless vs. stented aortic valve bioprostheses: a prospective randomized controlled trial. Eur Heart J. 2007;28(19):2369-2374. [pmid: 17670757].
27 Efskind L, Nitter-Hauge S, Hall KV, et al. Aortic and mitral valve replacement with two different disc prostheses. A randomized and comparative study. J Cardiovasc Surg (Torino). 1973. Spec No: 393–398.
28 Eichinger WB, Botzenhardt F, Keithahn A, et al. Exercise hemodynamics of bovine versus porcine bioprostheses: a prospective randomized comparison of the mosaic and perimount aortic valves. J Thorac Cardiovasc Surg. 2005;129(5):1056-1063. [pmid: 15867780].
29 Eichinger WB, Botzenhardt F, Guenzinger R, et al. The effective orifice area/patient aortic annulus area ratio: a better way to compare different bioprostheses? A prospective randomized comparison of the Mosaic and Perimount bioprostheses in the aortic position. J Heart Valve Dis. 2004;13(3):382-388. discussion 388–389. [pmid: 15222284].
30 Fiore AC, Barner HB, Swartz MT, et al. Mitral valve replacement: randomized trial of St. Jude and Medtronic Hall prostheses. Ann Thorac Surg. 1998;66(3):707-712. discussion 712–713. [pmid: 9768919].
31 Fiore AC, Swartz M, Grunkemeier G, et al. Valve replacement in the small aortic annulus: prospective randomized trial of St. Jude with Medtronic Hall. Eur J Cardiothorac Surg. 1997;11(3):485-491. discussion 491–492. [pmid: 9105813].
32 Graham R, Thambyrajah J, Stewart M, et al. Improved haemodynamic profile and left ventricular function following aortic valve replacement with a stentless rather than stented bioprosthesis: a randomised controlled trial. Heart. 2005;91:A18.
33 Gross C, Harringer W, Mair R, et al. Aortic valve replacement: is the stentless xenograft an alternative to the homograft? Early results of a randomized study. Ann Thorac Surg. 1995;60(2 Suppl):S418-S421. [pmid: 7646200].
34 Gross C, Harringer W, Beran H, et al. Aortic valve replacement: is the stentless xenograft an alternative to the homograft? Midterm results. Ann Thorac Surg. 1999;68(3):919-924. [pmid: 10509984].
35 Guenzinger R, Eichinger WB, Hettich I, et al. A prospective randomized comparison of the Medtronic Advantage Supra and St Jude Medical Regent mechanical heart valves in the aortic position: is there an additional benefit of supra-annular valve positioning?. J Thorac Cardiovasc Surg. 2008;136(2):462-471. [pmid: 18692658].
36 Horstkotte D, Haerten K, Herzer JA, et al. Five-year results after randomized mitral valve replacement with Bjork-Shiley. Lillehei-Kaster, and Starr-Edwards prostheses. Thorac Cardiovasc Surg. 1983;31(4):206-214. [pmid: 6195755].
37 Jasinski MJ, Ulbrych P, Kolowca M, et al. Early regional assessment of LV mass regression and function after stentless valve replacement: comparative randomized study. Heart Surgery Forum. 2004;7(5):E462-E465. discussion E462–465. [pmid: 15799926].
38 John A, Khan Z, Kuo J, et al. A prospective randomized comparison of Medtronic Mosaic and Carpentier-Edwards-SAV in the aortic position: an interim report. J Heart Valve Dis. 2006;15(3):441-445. [pmid: 16784086].
39 Kim YI, Lesaffre E, Scheys I, et al. The Monostrut versus Medtronic Hall prosthesis: a prospective randomized study. J Heart Valve Dis. 1994;3(3):254-259. [pmid: 8087261].
40 Kleine P, Hasenkam MJ, Nygaard H, et al. Tilting disc versus bileaflet aortic valve substitutes: intraoperative and postoperative hemodynamic performance in humans. J Heart Valve Dis. 2000;9(2):308-311. discussion 311–312. [pmid: 10772054].
41 Kuntze CE, Blackstone EH, Ebels T. Thromboembolism and mechanical heart valves: a randomized study revisited. Ann Thorac Surg. 1998;66(1):101-107. [pmid: 9692447].
42 Kuntze CE, Ebels T, Eijgelaar A, et al. Rates of thromboembolism with three different mechanical heart valve prostheses: randomised study. Lancet. 1989;1(8637):514-7. [pmid: 2564058].
43 Kvidal P, Bergstrom R, Malm T, et al. Long-term follow-up of morbidity and mortality after aortic valve replacement with a mechanical valve prosthesis. Eur Heart J. 2000;21(13):1099-1111. [pmid: 10843828].
44 Lehmann S, Walther T, Kempfert J, et al. Stentless versus conventional xenograft aortic valve replacement: midterm results of a prospectively randomized trial. Ann Thorac Surg. 2007;84(2):467-472. [pmid: 17643617].
45 Levang OW. Aortic valve replacement. A randomized study comparing the Bjork-Shiley and Lillehei-Kaster disc valves. Peroperative haemodynamic evaluation and early results. Scand J Thorac Cardiovasc Surg. 1978;12(3):197-205. [pmid: 725560].
46 Levang OW. Aortic valve replacement. A randomized study comparing Bjork-Shiley and Lillehei-Kaster disc valves. Haematological evaluation. Scand J Thorac Cardiovasc Surg. 1979;13(3):215-220. [pmid: 542823].
47 Levang OW, Nitter-Hauge S, Levorstad K, et al. Aortic valve replacement. A randomized study comparing the Bjork-Shiley and Lillehei-Kaster disc valves. Late haemodynamics related to clinical results. Scand J Thorac Cardiovasc Surg. 1979;13(3):199-213. [pmid: 161652].
48 Levang OW, Levorstad K, Haugland T. Aortic valve replacement. A randomized study comparing the Bjork-Shiley and Lillehei-Kaster disc valves. Transvalvular regurgitation and occurrence of paravalvular fistulas. Scand J Thorac Cardiovasc Surg. 1980;14(1):7-19. [pmid: 7375893].
49 Lim KHH, Caputo M, Ascione R, et al. Prospective randomized comparison of CarboMedics and St Jude Medical bileaflet mechanical heart valve prostheses: an interim report. J Thorac Cardiovasc Surg. 2002;123(1):21-32. [pmid: 11782752].
50 Bryan AJ, Rogers CA, Bayliss K, et al. Prospective randomized comparison of CarboMedics and St. Jude Medical bileaflet mechanical heart valve prostheses: ten-year follow-up. J Thorac Cardiovasc Surg. 2007;133(3):614-622. [pmid: 17320553].
51 Lundblad R, Hagen OM, Smith G, et al. The CarboMedics supraannular top hat valve improves prosthesis size in the aortic root. J Heart Valve Dis. 2001;10(2):196-201. [pmid: 11297206].
52 Maselli D, Pizio R, Bruno LP, et al. Left ventricular mass reduction after aortic valve replacement: homografts, stentless and stented valves. Ann Thorac Surg. 1999;67(4):966-971. [pmid: 10320236].
53 Melina G, De Robertis F, Gaer JAR, et al. Mid-term pattern of survival, hemodynamic performance and rate of complications after medtronic freestyle versus homograft full aortic root replacement: results from a prospective randomized trial. J Heart Valve Dis. 2004;13(6):972-975. discussion 975–976. [pmid: 15597592].
54 Melina G, Mitchell A, Amrani M, et al. Transvalvular velocities after full aortic root replacement: results from a prospective randomized trial between the homograft and the Medtronic Freestyle bioprosthesis. J Heart Valve Dis. 2002;11(1):54-58. discussion 58–59. [pmid: 11843506].
55 Mikaeloff P, Jegaden O, Ferrini M, et al. Prospective randomized study of St Jude Medical versus Bjork-Shiley or Starr-Edwards 6120 valve prostheses in the mitral position. Three hundred and fifty-seven patients operated on from 1979 to December 1983. J Cardiovasc Surg (Torino). 1989;30(6):966-975.
56 Miraldi F, Spagnesi L, Tallarico D, et al. Sorin stentless pericardial valve versus Carpentier-Edwards Perimount pericardial bioprosthesis: Is it worthwhile to struggle?. Int J Cardiol. 2007;118(2):253-255. [pmid: 17045674].
57 Murday AJ, Hochstitzky A, Mansfield J, et al. A prospective controlled trial of St. Jude versus Starr Edwards aortic and mitral valve prostheses. Ann Thorac Surg. 2003;76(1):66-73. discussion 73–74. [pmid: 12842515].
58 Otero E, Pomar JL, Revuelta JM, et al. Comparative evaluation of small-size Sorin Slimline and St. Jude HP heart valve prostheses. Ann Thorac Surg. 2005;79(4):1284-1290. [pmid: 15797063].
59 Perez de Arenaza D, Lees B, Flather M, et al. Randomized comparison of stentless versus stented valves for aortic stenosis: effects on left ventricular mass. Circulation. 2005;112(17):2696-2702. [pmid: 16230487].
60 Rostad H, Simonsen S, Nitter-Hauge S. Combined aortic and mitral valve replacement. A randomized study comparing the Bjork-Shiley and Lillehei-Kaster disc valve. Thorac Cardiovasc Surg. 1979;27(5):308-312. [pmid: 524332].
61 Santini F, Bertolini P, Montalbano G, et al. Hancock versus stentless bioprosthesis for aortic valve replacement in patients older than 75 years. Ann Thorac Surg. 1998;66(6 Suppl):S99-S103. [pmid: 9930426].
62 Santini F, Dyke C, Edwards S, et al. Pulmonary autograft versus homograft replacement of the aortic valve: a prospective randomized trial. J Thorac Cardiovasc Surg. 1997;113(5):894-899. discussion 899–900. [pmid: 9159623].
63 Schaff H, Carrel T, Steckelberg JM, et al. Artificial Valve Endocarditis Reduction Trial (AVERT): protocol of a multicenter randomized trial. J Heart Valve Dis. 1999;8(2):131-139. [pmid: 10224570].
64 Schaff HV, Carrel TP, Jamieson WRE, et al. Paravalvular leak and other events in silzone-coated mechanical heart valves: a report from AVERT. Ann Thorac Surg. 2002;73(3):785-792. [pmid: 11899956].
65 Englberger L, Schaff HV, Jamieson WRE, et al. Importance of implant technique on risk of major paravalvular leak (PVL) after St. Jude mechanical heart valve replacement: a report from the Artificial Valve Endocarditis Reduction Trial (AVERT). Eur J Cardiothorac Surg. 2005;28(6):838-843. [pmid: 16275007].
66 Grunkemeier GL, Jin R, Im K, et al. Time-related risk of the St. Jude Silzone heart valve. Eur J Cardiothorac Surg. 2006;30(1):20-27. [pmid: 16730188].
67 Seitelberger R, Bialy J, Gottardi R, et al. Relation between size of prosthesis and valve gradient: comparison of two aortic bioprosthesis. Eur J Cardiothorac Surg. 2004;25(3):358-363. [pmid: 15019661].
68 Sensky PR, Loubani M, Keal RP, et al. Does the type of prosthesis influence early left ventricular mass regression after aortic valve replacement? Assessment with magnetic resonance imaging. Am Heart J. 2003;146(4):E13. [pmid: 14564336].
69 Totaro P, Degno N, Zaidi A, et al. Carpentier-Edwards PERIMOUNT Magna bioprosthesis: a stented valve with stentless performance?. J Thorac Cardiovasc Surg. 2005;130(6):1668-1674. [pmid: 16308014].
70 Vitale N, Caldarera I, Muneretto C, et al. Clinical evaluation of St Jude Medical Hemodynamic Plus versus standard aortic valve prostheses: The Italian multicenter, prospective, randomized study. J Thorac Cardiovasc Surg. 2001;122(4):691-698. [pmid: 11581600].
71 Walther T, Falk V, Langebartels G, et al. Prospectively randomized evaluation of stentless versus conventional biological aortic valves: impact on early regression of left ventricular hypertrophy. Circulation. 1999;100:II6-10. [pmid: 10567271].
72 Walther T, Falk V, Langebartels G, et al. Regression of left ventricular hypertrophy after stentless versus conventional aortic valve replacement. Semin Thorac Cardiovasc Surg. 1999;11(4 Suppl 1):18-21. [pmid: 10660161].
73 Walther T, Lehmann S, Falk V, et al. Prospectively randomized evaluation of stented xenograft hemodynamic function in the aortic position. Circulation. 2004;110:II74-78. [pmid: 15364842].
74 Wheatley DJ, Tolland MM, Pathi V, et al. Randomised, prospective evaluation of a new pericardial heart valve: outcome after seven years. Eur J Cardiothorac Surg. 1995;9(5):259-267. discussion 267–268. [pmid: 7662379].
75 Chaudhry MA, Raco L, Muriithi EW, et al. Porcine versus pericardial bioprostheses: eleven-year follow up of a prospective randomized trial. J Heart Valve Dis. 2000;9(3):429-437. discussion 437–438. [pmid: 10888102].
76 Williams RJ, Muir DF, Pathi V, et al. Randomized controlled trial of stented and stentless aortic bioprotheses: hemodynamic performance at 3 years. Semin Thorac Cardiovasc Surg. 1999;11(4 Suppl 1):93-97. [pmid: 10660174].
77 Wiseth R, Haaverstad R, Vitale N, et al. Prosthetic valve hemodynamics assessed by the left ventricular outflow tract area utilization index: a randomized study of the carbomedics reduced versus the Medtronic Hall valve. J Heart Valve Dis. 2005;14(4):518-522. [pmid: 16116879].
78 Akins CW, Hilgenberg AD, Vlahakes GJ, et al. Results of bioprosthetic versus mechanical aortic valve replacement performed with concomitant coronary artery bypass grafting. Ann Thorac Surg. 2002;74(4):1098-1106. [pmid: 12400752].
79 Bernet FH, Baykut D, Grize L, et al. Single-center outcome analysis of 1,161 patients with St. Jude medical and ATS open pivot mechanical heart valves. J Heart Valve Dis. 2007;16(2):151-158. [pmid: 17484464].
80 Bleiziffer S, Eichinger WB, Wagner I, et al. The Toronto root stentless valve in the subcoronary position is hemodynamically superior to the mosaic stented completely supra-annular bioprosthesis. J Heart Valve Dis. 2005;14(6):814-821. discussion 821. [pmid: 16359064].
81 Borger MA, Carson SM, Ivanov J, et al. Stentless aortic valves are hemodynamically superior to stented valves during mid-term follow-up: a large retrospective study. Ann Thorac Surg. 2005;80(6):2180-2185. [pmid: 16305867].
82 Bottio T, Rizzoli G, Caprili L, et al. Biological versus mechanical aortic prosthesis? A nineteen-year comparison in a propensity-matched population. J Heart Valve Dis. 2005;14(4):493-500. [pmid: 16116876].
83 Bove T, Van Belleghem Y, Francois K, et al. Stentless and stented aortic valve replacement in elderly patients: Factors affecting midterm clinical and hemodynamical outcome. Eur J Cardiothorac Surg. 2006;30(5):706-713. [pmid: 16950630].
84 Carrier M, Hebert Y, Pellerin M, et al. Tricuspid valve replacement: an analysis of 25 years of experience at a single center. Ann Thorac Surg. 2003;75(1):47-50. [pmid: 12537191].
85 Dalrymple-Hay MJ, Leung Y, Ohri SK, et al. Tricuspid valve replacement: bioprostheses are preferable. J Heart Valve Dis. 1999;8(6):644-648. [pmid: 10616242].
86 de la Fuente A, Sanchez R, Imizcoz A, et al. Intact Medtronic and Carpentier Edwards S.A.V.: clinical and hemodynamic outcomes over 13 years. Cardiovasc Surg. 2003;11(2):139-144. [pmid: 12664049].
87 Del Rizzo DF, Abdoh A. Clinical and hemodynamic comparison of the Medtronic Freestyle and Toronto SPV stentless valves. J Card Surg. 1998;13(5):398-407. [pmid: 10440656].
88 Do QB, Pellerin M, Carrier M, et al. Clinical outcome after isolated tricuspid valve replacement: 20-year experience. Can J Cardiol. 2000;16(4):489-493. [pmid: 10787464].
89 Eberlein U, von der Emde J, Rein J, et al. Thromboembolic and bleeding complications after mitral valve replacement. Eur J Cardiothorac Surg. 1990;4(11):605-612. [pmid: 2268440].
90 Hayashi J, Saito A, Yamamoto K, et al. Is a bioprosthesis preferable in tricuspid valve replacement?. Thorac Cardiovasc Surg. 1996;44(5):230-233. [pmid: 8948549].
91 Houel R, Le Besnerais P, Soustelle C, et al. Lack of durability of the Mitroflow valve does not affect survival. J Heart Valve Dis. 1999;8(4):368-374. discussion 374–375. [pmid: 10461235].
92 Jamieson WRE, von Lipinski O, Miyagishima RT, et al. Performance of bioprostheses and mechanical prostheses assessed by composites of valve-related complications to 15 years after mitral valve replacement. J Thorac Cardiovasc Surg. 2005;129(6):1301-1308. [pmid: 15942570].
93 Jasinski MJ, Hayton J, Kadziola Z, et al. Hemodynamic performance after stented vs stentless aortic valve replacement. J Cardiovasc Surg (Torino). 2002;43(3):313-317.
94 Jin XY, Zhang ZM, Gibson DG, et al. Effects of valve substitute on changes in left ventricular function and hypertrophy after aortic valve replacement. Ann Thorac Surg. 1996;62(3):683-690. [pmid: 8783993].
95 Kaplan M, Kut MS, Demirtas MM, et al. Prosthetic replacement of tricuspid valve: bioprosthetic or mechanical. Ann Thorac Surg. 2002;73(2):467-473. [pmid: 11845861].
96 Kulik A, Bedard P, Lam BK, et al. Mechanical versus bioprosthetic valve replacement in middle-aged patients. Eur J Cardiothorac Surg. 2006;30(3):485-491. [pmid: 16857373].
97 Kurlansky PA, Williams DB, Traad EA, et al. The valve of choice in elderly patients and its influence on quality of life: a long-term comparative study. J Heart Valve Dis. 2006;15(2):180-189. discussion 190. [pmid: 16607898].
98 Le Tourneau T, Savoye C, McFadden EP, et al. Mid-term comparative follow-up after aortic valve replacement with Carpentier-Edwards and Pericarbon pericardial prostheses. Circulation. 1999;100:II11-16. [pmid: 10567272].
99 Le Tourneau T, Vincentelli A, Fayad G, et al. Ten-year echocardiographic and clinical follow-up of aortic Carpentier-Edwards pericardial and supraannular prosthesis: a case-match study. Ann Thorac Surg. 2002;74(6):2010-2015. [pmid: 12643388].
100 Milano A, Guglielmi C, De Carlo M, et al. Valve-related complications in elderly patients with biological and mechanical aortic valves. Ann Thorac Surg. 1998;66(6 Suppl):S82-S87. [pmid: 9930423].
101 Munro AI, Jamieson WR, Tyers GF, et al. Tricuspid valve replacement: porcine bioprostheses and mechanical prostheses. Ann Thorac Surg. 1995;60:S470-473. discussion S473–474. [pmid: 7646210].
102 Ninet J, Tronc F, Robin J, et al. Mechanical versus biological isolated aortic valvular replacement after the age of 70: equivalent long-term results. Eur J Cardiothorac Surg. 1998;13(1):84-89. [pmid: 9504735].
103 Peterseim DS, Cen YY, Cheruvu S, et al. Long-term outcome after biologic versus mechanical aortic valve replacement in 841 patients. J Thorac Cardiovasc Surg. 1999;117(5):890-897. [pmid: 10220680].
104 Prasongsukarn K, Jamieson WRE, Lichtenstein SV. Performance of bioprostheses and mechanical prostheses in age group 61–70 years. J Heart Valve Dis. 2005;14(4):501-508. [pmid: 16116877].
105 Ratnatunga CP, Edwards MB, Dore CJ, et al. Tricuspid valve replacement: UK Heart Valve Registry mid-term results comparing mechanical and biological prostheses. Ann Thorac Surg. 1998;66(6):1940-1947. [pmid: 9930473].
106 Rizzoli G, Vendramin I, Nesseris G, et al. Biological or mechanical prostheses in tricuspid position? A meta-analysis of intra-institutional results. Ann Thorac Surg. 2004;77(5):1607-1614. [pmid: 15111151].
107 Ruel M, Chan V, Bedard P, et al. Very long-term survival implications of heart valve replacement with tissue versus mechanical prostheses in adults <60 years of age. Circulation. 2007;116(11 Suppl):I294-I300. [pmid: 17846320].
108 Schelbert EB, Vaughan-Sarrazin MS, Welke KF, et al. Valve type and long-term outcomes after aortic valve replacement in older patients. Heart. 2008;94(9):1181-1188. [pmid: 18070945].
109 Scully HE, Armstrong CS. Tricuspid valve replacement. Fifteen years of experience with mechanical prostheses and bioprostheses. J Thorac Cardiovasc Surg. 1995;109(6):1035-1041. [pmid: 7776666].
110 Smedira NG, Blackstone EH, Roselli EE, et al. Are allografts the biologic valve of choice for aortic valve replacement in nonelderly patients? Comparison of explantation for structural valve deterioration of allograft and pericardial prostheses. J Thorac Cardiovasc Surg. 2006;131(3):558-564. e4. [pmid: 16515905].
111 Tsialtas D, Bolognesi R, Beghi C, et al. Stented versus stentless bioprostheses in aortic valve stenosis: effect on left ventricular remodelling. Heart Surgery Forum. 2007;10(3):E205-E210. [pmid: 17389213].
112 Valfre C, Rizzoli G, Zussa C, et al. Clinical results of Hancock II versus Hancock Standard at long-term follow-up. J Thorac Cardiovasc Surg. 2006;132(3):595-601. [pmid: 16935115].
113 Van Nooten GJ, Caes F, Taeymans Y, et al. Tricuspid valve replacement: postoperative and long-term results. J Thorac Cardiovasc Surg. 1995;110(3):672-679. [pmid: 7564433].
114 Vitale N, De Feo M, De Siena P, et al. Tilting-disc versus bileaflet mechanical prostheses in the aortic position: a multicenter evaluation. J Heart Valve Dis. 2004;13(Suppl 1):S27-S34. [pmid: 15224997].
115 Westaby S, Horton M, Jin XY, et al. Survival advantage of stentless aortic bioprostheses. Ann Thorac Surg. 2000;70(3):785-90. discussion 790–791. [pmid: 11016310].
116 Westaby S, Jonson A, Payne N, et al. Does the use of a stentless bioprosthesis increase surgical risk?. Semin Thorac Cardiovasc Surg. 2001;13(4 Suppl 1):143-147. [pmid: 11805963].
117 Wu Y, Gregorio R, Renzulli A, et al. Mechanical heart valves: are two leaflets better than one?. J Thorac Cardiovasc Surg. 2004;127(4):1171-1179. [pmid: 15052219].