# Evidence Tables

Evidence Table 1 Systematic reviews comparing various conventional heart valves (Question 2)

Study | Studies and interventions | Patients | Outcomes assessed | Relative risks/other summary effect measures | Comments/quality scoring
Kassai, Gueyffier, Cucherat, et al., 2000 1 | No. of included studies: RCTs: 3 (2 in adults) Observational: 0 Study countries: NR Study intervention: Mechanical heart valves (Bjorkshiley, Lillehei-Kaster-children) Comparator treatment(s): Bioprosthetic heart valves (Carpentier-Edward, Hancock, Angell-Shiley-children) Clinical setting 1: OR: All 3 Clinical setting 2: NR Implantation technique: Surgical: 3 Percutaneous: 0 Surgeon characteristics: NR | No. of patients: RCTs: 1229 (1011 adults) Observational: 0 Age: Adults 2 trials Children 1 trial Race/ethnicity: NR Comorbidities: NR Surgical indication(s): Aortic valve disease: 605 Mitral valve disease: 553 Aortic and mitral valve disease: 61 | Primary: 1) All-cause mortality Secondary: 2) In-hospital mortality 3) Cardiac mortality 4) Reoperation 5) Bleeding 6) Thromboembolism 7) Endocarditis Length of follow-up: Mean of 11–12 yr for adults | Relative risks (with 95% CIs) for mechanical heart valves compared to bioprosthetic for 2 adult studies at 11 yr Primary outcome: 1) All-cause mortality at 11 yr: 0.94 (0.84 to 1.06) Secondary outcomes: 2) In-hospital mortality: 0.75 (0.5 to 1.13) 3) Cardiac mortality: 0.98 (0.79 to 1.21) 4) Reoperation: 0.4 (0.28 to 0.58); p = 0.059 for heterogeneity 5) Bleeding at 11 yr: 1.65 (1.25 to 2.18) 6) Thromboembolism: 0.97 (0.71 to 1.34) 7) Endocarditis: 0.57 (0.34 to 0.95); p = 0.001 for heterogeneity | Comments: Internal inconsistencies make some results suspect Quality assessment: Focused clinical question?: Yes Detailed and exhaustive search?: Can‘t tell; databases appropriate, search terms not given Inclusion/exclusion criteria defined and appropriate?: Yes Included studies evaluated for quality?: No Assessments reproducible?: Yes Analysis for variability?: Yes Results combined appropriately?: Yes Publication bias assessed?: Yes Both benefits and harms assessed?: Yes Conclusions supported by data?: Yes Objective(s) of review: To compare effects on mortality and morbidity for mechanical vs. bioprosthetic heart valves
Kunadian, Vijayalakshmi, Thornley, et al., 2007 2 | No. of included studies: RCTs: 11 Observational: 0 Study countries: UK (5) Italy (3) Germany (2) Canada (1) Study intervention: Stentless valve (Prima Plus-Edwards Lifesciences, Freedom-Sorin Bomedica Cardio, Freestyle-Medtronic, Toronto-St Jude, Biocor-Sorin Biomedica) Comparator treatment(s): Stented valve (Perimount-Carpentier-edwards, Edwards Lifesciences, More-Sorin Biomedica, Mosaic-Medtronic, Intact-Medtronic, Hancock II-Medtronic) Clinical setting –1: NR, but all presumably OR Clinical setting – 2: NR Implantation technique: Surgical: 11 Percutaneous: 0 Surgeon characteristics: NR | No. of patients: RCTs: 919 (474 stentless; 445 stented) Observational: 0 Age: NR Race/ethnicity: NR Comorbidities: NR Surgical indication(s): Aortic valve replacement | Primary: 1) Left ventricular mass regression index Secondary: 2) Cross-clamp time 3) Bypass time 4) Post-operative mean and peak aortic gradient 5) Effective orifice area index 6) Mortality at ≤ 1 yr Length of follow-up: NR | Primary outcome: 1) LVMI at 6 mo (6 studies, n = 599): WMD −6.42 (95% CI, −11.63 to −1.21) for stentless vs. stented; p < 0.01 for heterogeneity LVMI at ≥ 12 mo (5 studies, n = 550): WMD 1.19 (−4.15 to 6.53) for stentless vs. stented; p = 0.35 for heterogeneity Secondary outcomes: 2) Cross-clamp time (10 studies): WMD 23.5 min longer (20.4 to 26.1) for stentless vs. stented 3) Bypass time (9 studies): WMD 29.0 min longer (24.4 to 34.0) for stentless vs. stented 4) Mean aortic gradient (number of studies NR): WMD −3.57 mmHg for stentless (−4.36 to −2.78) vs. stented Peak gradient (number of studies NR): WMD −5.80 mmHg for stentless (−6.90 to −4.69) vs. stented 5) Effective orifice area index (number of studies NR): Higher for stentless vs. stented; value NR, p < 0.01 6) Mortality at ≤ 1 yr (7 trials, n = 807): OR = 0.91 (0.52 to 1.57) for stentless vs. stented; p = 0.70 for heterogeneity | Comments: None Quality assessment: Focused clinical question?: Yes Detailed and exhaustive search?: Yes (though only 1995–2006) Inclusion/exclusion criteria defined and appropriate?: Yes Included studies evaluated for quality?: Yes Assessments reproducible?: Yes Analysis for variability?: Yes Results combined appropriately?: Yes Publication bias assessed?: Yes Both benefits and harms assessed?: Yes Conclusions supported by data?: Yes Objective(s) of review: To determine whether stentless valves vs. conventional stented valves give greater left ventricular mass regression
Lund and Bland, 2006 3 | No. of included studies: RCTs: 0 Observational: 32 articles describing 38 case series Study countries: NR Study intervention: Mechanical heart valves (St. Jude bileaflet disc, mixed disc valves, Medtronic-Hall tilting disc) Comparator treatment(s): Bioprosthetic heart valves (Carpentier-Edwards [CE] Perimount pericardial, CE porcine standard, CE porcine supra-annular, Hancock II and MO porcine, Mitroflow pericardial, mixed biologic, Biocor porcine) Clinical setting – 1: NR, but all presumably OR Clinical setting– 2: NR Implantation technique: Surgical: 32 Percutaneous: 0 Surgeon characteristics: NR | No. of patients: RCTs: 0 Observational: 17,439 Age: Mean mechanical: 58.0 Mean bioprosthetic: 68.8 Race/ethnicity: NR Comorbidities: Concomitant CABG: 15.7% mechanical 34.1% bioprosthetic NYHA class III or IV: 64.6% mechanical, 69.6% bioprosthetic Surgical indication(s): Aortic valve replacement for the following indications: -Aortic regurgitation (28.7% mechanical; 16.5% bioprosthetic) -Aortic stenosis (50.9% mechanical; 68.6% bioprosthetic); -Endocarditis (6.8% mechanical, 2.2% bioprosthetic) | Primary: 1) Mortality Secondary: None Length of follow-up: Mean 6.4 yr for mechanical (range, 3.9 to 10.8), and 5.3 yr (2.6 to 10.1) for bioprosthetic | Primary outcome: 1) −0.23 deaths (95%CI, −0.99 to 0.63) per 100 patient-years for bioprosthetic vs. mechanical, adjusting for age, proportion with NYHA class III or IV, and aortic regurgitation as the indication Secondary outcomes: None | Comments: None Quality assessment: Focused clinical question?: Yes Detailed and exhaustive search?: Partially; well-described strategy, but may be too narrow Inclusion/exclusion criteria defined and appropriate?: Yes Included studies evaluated for quality?: No Assessments reproducible?: No Analysis for variability?: Yes, graphically Results combined appropriately?: Yes Publication bias assessed?: No Both benefits and harms assessed?: Yes Conclusions supported by data?: Yes Objective(s) of review: To determine whether currently available mechanical heart valves (bileaftet and single disc) vs. stented bioprosthetic (porcine and bovine) have differential effects on crude mortality
Puvimanasinghe, Takkenberg, Edwards, et al., 2004 4 and Puvimanasinghe, Takkenberg, Eijkemans, et al., 2003 5 | No. of included studies: NR by study design – 9 reports for St. Jude aortic valve prostheses (7 retrospective, 2 prospective) and 13 reports for stented porcine bioprostheses (8 retrospective, 3 prospective, 2 NR) Study countries: NR Study intervention: St. Jude mechanical aortic valve prosthesis Comparator treatment(s): Stented porcine bioprosthesis Clinical setting –1: NR, but presumably all OR Clinical setting – 2: NR Implantation technique: Surgical: 22 Percutaneous: 0 Surgeon characteristics: NR | No. of patients: NR by study design; St. Jude mechanical: 4274 pts Porcine bioprostheses: 9007 pts Age: Mean St. Jude: 59.1 Mean porcine: 65.4 Race/ethnicity: NR Comorbidities: Concomitant CABG: 30% St. Jude 37% porcine Surgical indication(s): Aortic valve replacement | Primary: 1) Life expectancy based on microsimulation 2) Event-free life expectancy based on microsimulation Secondary: Occurrence rate per 100 patient-years of following: 3) Valve thrombosis 4) Thromboembolism 5) Hemorrhage 6) Endocarditis 7) Non-structural dysfunction 8) Structural valvular deterioration Length of follow-up: Total follow up in patient-years was 25,726 for St. Jude mechanical, and 54,151 for porcine bioprosthesis | Primary outcome: 1) Life expectancy for a 65 y/o man: 10.4 yr mechanical vs. 10.7 yr bioprostheses 2) Event-free life expectancy for 65 y/o man: 7.7 yr mechanical vs. 8.4 yr bioprosthesis Concomitant CABG decreased life expectancy Secondary outcomes: Occurrence rate per 100 patient-years: 3) Valve thrombosis: Mechanical: 0.16 Bioprosthesis: 0.01 4) Thromboembolism: Mechanical: 1.6 Bioprosthesis: 1.3 5) Hemorrhage: Mechanical: 1.6 Bioprosthesis: 0.4 6) Endocarditis: Mechanical: 3.9 in first 6 mo, 0.66 after 6 mo Bioprosthesis: 3.2 in first 6 mo; 0.48 after 6 mo 7) Non-structural dysfunction: Mechanical: 0.29 Bioprosthesis: 0.3 8) Structural valvular deterioration: Mechanical: 0 Bioprosthesis: 1.2 | Comments: None Quality assessment: Focused clinical question?: Yes Detailed and exhaustive search?: Probably no; search terms not clear, PubMed and references of included studies only Inclusion/exclusion criteria defined and appropriate?: Can‘t tell Included studies evaluated for quality?: No Assessments reproducible?: No Analysis for variability?: No Results combined appropriately?: Partially; required standard definitions as part of inclusion criteria, but didn‘t discuss further Publication bias assessed?: No Both benefits and harms assessed?: Yes Conclusions supported by data?: Uncertain Objective(s) of review: To predict age and sex-specific outcomes of patients after aortic valve replacement with St. Jude mechanical valves and stented porcine bioprosthesis
Puvimanasinghe, Takkenberg, Eijkemans, et al., 2006 6 | No. of included studies: NR by study design – 8 reports on the Carpentier-Edwards pericardial valve, and 5 on the Carpentier-Edwards supraannular valve Study countries: NR Study intervention: Carpentier-Edwards pericardial aortic valve replacement Comparator treatment(s): Carpentier-Edwards supraannular bioprosthetic aortic valve replacement Clinical setting – 1: NR, but presumably all OR Clinical setting –2: NR Implantation technique: Surgical: 13 Percutaneous: 0 Surgeon characteristics: NR | No. of patients: NR by study design; C–E pericardial: 2685 pts C-E porcine supra-annular: 3796 pts Age: Mean C-E pericardial: 66.9 Mean C-E porcine supraannular: 69.8 Race/ethnicity: NR Comorbidities: NR Surgical indication(s): NR | Primary: 1) Life expectancy based on microsimulation 2) Event-free life expectancy based on microsimulation Secondary: Occurrence rate per 100 patient-years of following: 3) Valve thrombosis 4) Thromboembolism 5) Hemorrhage 6) Endocarditis 7) Non-structural dysfunction Length of follow-up: 18 yr for C-E pericardial valves, and up to 20 yr for C-E porcine supraannular valves | Primary outcome: 1) Life expectancy for a 65 y/o man: 10.8 yr CE pericardial vs. 10.9 yr CE supraannular 2) Event-free life expectancy for 65 y/o man: 9.0 yr CE pericardial vs. 8.8 yr CE supraannular Secondary outcomes: Occurrence rate per 100 patient-years: 3) Valve thrombosis: CE pericardial: 0.03 CE supraannular: 0.02 4) Thromboembolism: CE pericardial: 1.35 CE supraannular: 1.76 5) Hemorrhage: CE pericardial: 0.43; CE supraannular: 0.46 6) Endocarditis: CE pericardial: 0.62 CE supraannular: 0.39 7) Non-structural dysfunction: CE pericardial: 0.13 CE supraannular: 0.61 | Comments: None Quality assessment: Focused clinical question?: Yes Detailed and exhaustive search?: No, only 7 yr, only English, restrictive terms Inclusion/exclusion criteria defined and appropriate?: Can‘t tell Included studies evaluated for quality?: No Assessments reproducible?: No Analysis for variability?: No Results combined appropriately?: No Publication bias assessed?: No Both benefits and harms assessed?: Yes Conclusions supported by data?: Uncertain Objective(s) of review: To compare long-term outcomes in patients undergoing aortic valve replacement with Carpentier-Edwards bovine pericardial vs. Carpentier-Edwards porcine supraannular bioprosthesis.
Rizzoli, Vendramin, Nesseris, et al., 2004 7 | No. of included studies: NR by study design 11 studies referenced Study countries: Belgium = 1; Canada = 3; France = 2; Japan = 1; UK = 2; Turkey = 1; Italy = 1 Study intervention: Bioprosthetic valve replacement in the tricuspid position Comparator treatment(s): Mechanical valve replacement in the tricuspid position Clinical setting –1: NR, but presumably all OR Clinical setting –2: NR Implantation technique: Surgical: 11 Percutaneous: 0 Surgeon characteristics: NR | No. of patients: NR by study design; Bioprosthetic: 646 Mechanical: 514 Age: Mean for all pts: 49.3 Race/ethnicity: NR Comorbidities: Ratio of NYHA class III and IV in bioprosthetic to mechanical valves: 0.81 Surgical indication(s): Tricuspid valve replacement | Primary: 1) Late survival of pts after operation Secondary: 2) Freedom from reoperation 3) Reoperation-free survival Length of follow-up: Mean duration: 6.8 yr For individual studies: Van Nooten: 7.8 yr Scully: 6.3 yr Munro: 3.7 yr Farinas: 9.5 yr Hayashi: 6.7 yr Ratnatunga: NR Dalrymple: 8.1 yr Do: 5.6 yr Kaplan: 6.3 yr Carrier: 4.0 yr Local Data: 7.4 yr | Primary outcome: 1) Survival: Hazard ratio for mechanical vs. bioprosthetic (8 studies) = 1.07 (0.84 to 1.35) Secondary outcomes: 2) Freedom from reoperation: Hazard ratio for mechanical vs. bioprosthetic (3 studies) = 1.24 (0.67 to 2.31) 3) Reoperation-free survival: Hazard ratio for mechanical vs. bioprosthetic (2 studies) = 0.86 (0.70 to 1.05) | Comments: None Quality assessment: Focused clinical question?: No Detailed and exhaustive search?: Partially; appropriate databases, poor search terms Inclusion/exclusion criteria defined and appropriate?: No; only criteria was “intra- institutional comparison of results of biological or mechanical TVR” Included studies evaluated for quality?: No Assessments reproducible?: No Analysis for variability?: No Results combined appropriately?: No Publication bias assessed?: No Both benefits and harms assessed?: No Conclusions supported by data?: Yes Objective(s) of review: In patients needing tricuspid valve replacement, does mechanical or bioprosthetic heart valve lead to better survival?

Evidence Table 2 Published studies of percutaneous heart valves (Questions 3–4)

Study | Study characteristics | Patients | Intervention | Outcomes | Adverse events | Comments
Al-Attar, Raffoul, Himbert, et al., 2009 8 | Country/countries: France Setting: NR Basic design: Case report Study objective(s): NR Duration of follow-up: 3 months | No. of patients: 1 Age: 81 Sex: Male Medical/functional status: NYHA III Surgical indication(s): Low cardiac output & acute renal failure Inclusion criteria: NR Exclusion criteria: NR | Valve name: Edwards SAPIEN THV Size of catheter: 26 mm Self- or balloon-expanding?: Balloon-expandable Implantation approach: Transapical Operator(s): NR | Successful implantation: 1/1 (100%) Hemodynamic outcomes: 1) Method of assessment: Echocardiography 2) Change in valve area: NR 3) Change in valve gradient: NR Clinical status outcomes: 1) Change in NYHA functional class: NR Survival: 1/1 (100%) at 3 months | Complications: - Pericardial effusion at 2 weeks -False aneurysm of LV Major cardiovascular/cerebrovascular events: NR Valve dysfunction: Leak: Negligible posterior leak (< 1/4)
Asgar, Mullen, Dela hunty, et al., 2009 9 | Country/countries: United Kingdom Setting: NR Basic design: Case report Study objective(s): NR Duration of follow- up: 5 months | No. of patients: 1 Age: 71 Sex: Female Medical/functional status: NR Surgical indication(s): Severe AS Inclusion criteria: NR Exclusion criteria: NR | Valve name: CoreValve Size of catheter: 18 Fr Self- or balloon-expanding?: Self Implantation approach: Axillary Operator(s): NR | Successful implantation: 1/1 (100%) Hemodynamic outcomes: NR Clinical status outcomes: NR Survival: 1/1 (100%) | Complications: None reported Major cardiovascular/cerebrovascular events: None reported Valve dysfunction: None reported
Bauer, Eltchaninoff, Tron, et al., 2004 10 | Country/countries: France Setting: NR Basic design: Case series Study objective(s): Apply tissue Doppler imaging to detect subtle improvement in global and regional LV systolic function immediately after PHV implantation Duration of follow- up: 1 mo after PHV implantation | No. of patients: 8 Age: 77 to 88 (mean 83 ± 3) Sex: Female: 6 (75%) Male: 2 (25%) Medical/functional status: NYHA class IV: 8 (100%) 2 (25%) in cardiogenic shock Surgical indication(s): - 8 (100%) had severe AS, with AVA averaging 0.59 ± 0.11 cm^2^ - Peak pressure gradient 78 ± 19 mm Hg - Mean pressure gradient 46 ± 15 mm Hg - LVEF averaged 48 ± 18% (22% to 73%), and LVEF was lower than 45% in 3 (38%) pts Inclusion criteria: - Symptomatic despite maximal medical therapy - Declined by 2 independent surgeons due to hemodynamic instability and associated severe comorbidities Exclusion criteria: NR | Valve name: Cribier Edwards (Not named in report) Size of catheter: NR Self- or balloon- expanding?: Balloon inflation: 23 mm diameter Implantation approach: Arterial retrograde in 2 (25%) Transseptal anterograde in 6 (75%) Operator(s): NR | Successful implantation: 8/8 (100%) Hemodynamic outcomes: 1) Change in valve area: 0.59 ± 0.11 → 1.69 ± 0.11 cm^2^ 2) Change in valve gradient: mean 46 ± 15 → 8 ± 3 mm Hg 3) Other: EF 48 ± 18% → 57 ± 12% Clinical status outcomes: Change in NYHA functional class: NR 30-day survival: 5/8 (63%) | Complications: LVEF increased from 48 ± 18% to 57 ± 12% (p < 0.0001) at 24 hr follow-up Valve dysfunction: - Leak: NR - Hemolysis: NR - Migration: NR - Infection: NR - Need for re- intervention: NR | Authors state that “percutaneous aortic valve replacement is characterized by an immediate enhancement of global and regional systolic function, even in patients with low ejection fraction.”
Bauernschmitt, Schreiber, Bleiziffer, et al., 2009 11 | Country/countries: Germany Setting: NR Basic design: Case report Study objective(s): NR Duration of follow- up: NR | No. of patients: 1 Age: 80 Sex: Female Medical/functional status: NR Surgical indication(s): Critical AS Inclusion criteria: NR Exclusion criteria: NR | Valve name: CoreValve Revalving System Size of catheter: NR Self- or balloon- expanding?: Self- expanding Implantation approach: Retrograde, via ascending aorta Operator(s): NR | Successful implantation: 1/1 (100%) Hemodynamic outcomes: 1) Aortography: NR 2) Echocardiography: NR 3) Change in valve gradient: NR Clinical status outcomes: Change in NYHA functional class: NR Survival: NR | Complications: NR Major cardiovascular/ cerebrovascular events: NR Valve dysfunction: NR
Berry, Asgar, Lamarche, et al., 2007 12 and Berry, Cartier, and Bonan, 2007 13 | Country/countries: Canada Setting: NR Basic design: Case series Study objective(s): Investigate whether novel therapeutic approaches may facilitate AVR outcomes for high-risk pts Outcomes: - 30-day mortality - In-hospital mortality - LVEF change - NT-BNP concentration change Duration of follow- up: 305 (270 to 326) days (from PAVR until 2/20/2007 [or until death]) | No. of patients: 13 informed consent Age: Median 82 (64 to 90) Sex: Female: 5 (46%); Male: 6 (54%) Medical/functional status: NYHA class III: 8 (73%) NYHA class IV: 3 (27%) Surgical indication(s): Severe AS Inclusion criteria: - Severe AS (aortic valve area index ≤ 0.6 cm2/m2 - Aorticannulus diameter of 20–23 mm - Sinotubular junction diameter ≤ 45 mm - Either pt age ≥ 80 yr with a logistic Euro- Score ≥ 20%, or age ≥ 65 yr plus at least one major disincentive for surgery (previous cardiac surgery, pulmonary artery systolic pressure > 60 mm Hg) Exclusion criteria: Peripheral arterial disease associated with significant tortuosity or an internal lumen diameter ≤ 7 mm | Valve name: CoreValve porcine bioprosthesis Size of catheter: 21 Fr Self- or balloon- expanding?: Self- expanding nitinol valve frame Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 11/13 (85%) Hemodynamic outcomes: 1) Change in valve area: 0.56 ± 0.19 → 1.3 ± 0.4 cm^2^ (p < 0.0001) 2) Change in valve gradient: mean 51 ± 19 → 9 ± 4 mm Hg (p < 0.00001) 3) Other: Mean LVEF 49 ± 17% → 56 ± 11% at 30 days Mean NT-BNP 10,059 ± 12,117 → 5,036 ± 7,790 pg/ml at 30 days Clinical status outcomes: Change in NYHA functional class: 1 patient improved by 2 points, and the other survivors improved by 1 point (p = 0.0006) 30-day survival: 1) 11/13 (85%) at 30 days 2) 7/13 (54%) at 1 year 3) 0 cardiac deaths within 30 days | Complications: - 2 (18%) non-cardiac deaths - 3 (27%) CKMB > 5X ULN - 3 (27%) new permanent pacemaker - 4 (36%) new LBBB - 8 (82%) blood transfusion - 2 (18%) platelet transfusion - 1 male had periprocedural stroke and died 5 days post-PAVR 30-day AEs: - 4 (36%) bradyarrhythmia - 2 (18%) major bleeding Valve dysfunction: Leak: Grade I (64%) Grade II (36%) | Author states this report provides “novel information on the versatility of PAVR, which in our hands was combined with percutaneous left heart circulatory support, PCI and PTA. A multidisciplinary approach with careful screening and postprocedure follow- up is necessary to ensure optimal procedural outcomes.”
Bleiziffer, Ruge, Mazzitelli, et al., 2009 14 | Country/countries: Germany Setting: Hybrid operating room with permanent angiography unit Basic design: Case series Study objective(s): “We will discuss the various techniques currently in use, all of which are now being performed at the German Heart Center I Munich. Furthermore, we will discuss the results that have been obtained to date, with follow-up times of up to 6 months.” Duration of follow- up: 6 months | No. of patients: 152 Age: 81 ± 7 Sex: Female: 87 (57%) Male:65 (43%) Medical/functional status: 97% NYHA III or IV Surgical indication(s): Patients either had a specific contraindication to conventional surgical aortic valve replacement, such as severe, extensive calcification of the ascending aorta, or they were very old and had major comorbidities Inclusion criteria: Specific contraindication to conventional surgical aortic valve replacement, or very old and had major comorbidities Exclusion criteria: NR | Valve name: Edwards- Sapien & CoreValve Size of catheter: E-S: 22–24 Fr CV: 18 Fr Self- or balloon- expanding?: E-S: Balloon-expanding CV: Self-expanding Implantation approach: Transfemoral retrograde (n = 121) Transapical (n = 26) Subclavian artery (n = 3) Ascending aorta (n = 2) Operator(s): NR | Successful implantation: 150/152 (99%) Hemodynamic outcomes: 1) Method of assessment: Echocardiography 2) Change in valve area: 0.65 ± 0.19 to 1.56 ± 0.4 cm^2^ at 6 mo 3) Change in valve gradient: Mean: 49 ± 17 to 11 ± 4 at 6 mo Clinical status outcomes: Change in NYHA functional class: 86% class I or II at 3 months; 83% class I or II at 6 months Survival: 134/152 alive at 30 days; 12 patients died later in 6-month course of follow-up | Complications: 1 pt – ruptured ascending aorta 1 pt – supravalvular dislocation of prosthesis 4 pts – intraoperative cardiac depression Major cardiovascular/ cerebrovascular events: 31 pts - third-degree atrioventricular block necessitating pacemaker 25 pts - vascular complications 8 pts – cerebrovascular events Valve dysfunction: Leak: Frequency of paravalvular leaks of grade ≥ 2 was 11% at time of discharge and 7% at 6 mo
Bojara, Mumme, Gerckens, et al., 2009 15 | Country/countries: Germany Setting: NR Basic design: Case report Study objective(s): Focus on an alternative arterial access for retrograde aortic valve implantation in patients in which the femoral/iliac arteries are not accessible Duration of follow- up: 30 days | No. of patients: 1 Age: 82 Sex: Male Medical/functional status: NYHA Class IV Surgical indication(s): Recurrent resting dyspnea Inclusion criteria: NR Exclusion criteria: NR | Valve name: Third- generation CoreValve Size of catheter: 18 Fr Self- or balloon- expanding?: Balloon- expanding Implantation approach: Subclavian artery approach Operator(s): NR | Successful implantation: 1/1 (100%) Hemodynamic outcomes: 1) Method of assessment: C-cath 2) Change in valve area: 0.6 cm^2^ to NR 3) Change in valve gradient: Peak: 85 mm Hg to “almost zero” intraoperatively Clinical status outcomes: Change in NYHA functional class: Class II/III Survival: 1/1 (100%) at 30 days | Complications: NR Major cardiovascular/ cerebrovascular events: NR Valve dysfunction: NR
Bollati, Moretti, Omede, et al., 2009 16 | Country/countries: Italy Setting: NR Basic design: Case series Study objective(s): NR Duration of follow-up: 12 days for one patient, and 3 weeks for the second patient. | No. of patients: 2 Age: Pt 1: 81 Pt 2: 70 Sex: Female: 2 (100%) Medical/functional status: NYHA III Surgical indication(s): Pt 1: Dyslipidemia, asymptomatic carotid artery disease, coronary artery disease symptomatic for effort angina Pt 2: Hypertension, insulin-dependent diabetes, obesity, previous episode of DVT and severe hepatic cirrhosis with secondary pancytopenia which had already caused severe esophageal bleeding in 2004 Inclusion criteria: NR Exclusion criteria: NR | Valve name: CoreValve Revalving System Size of catheter: 18 Fr Self- or balloon- expanding?: Self- expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 2/2 (100%) Hemodynamic outcomes: 1) Method of assessment: TTE C-cath 2) Change in valve area: NR 3) Change in valve gradient: “Almost complete resolution of aortic valve gradient” Clinical status outcomes: Change in NYHA functional class: NR Survival: Alive at discharge, 12 days, and 3 weeks after admission | Complications: - A third-degree atrioventricular block (requiring permanent pacemaker implantation) - Bleeding from the right femoral artery access (requiring implantation of two covered stents and blood transfusion) Major cardiovascular/ cerebrovascular events: NR Valve dysfunction: - Leak: “Moderate” - Other: Persistent bleeding from femoral site
Buellesfeld, Gerckens, and Grube, 2008 17 | Country/countries: Germany Setting: NR Basic design: Case report Study objective(s): NR Duration of follow- up: 3 mo | No. of patients: 1 Age: 93 Sex: Female Medical/functional status: NYHA class IV Logistic euroSCORE (mortality): 22.9% Surgical indication(s): Severe symptomatic aortic stenosis Inclusion criteria: Surgical valve replacement had been declined by 2 independent cardiovascular surgeons due to comorbidities Exclusion criteria: NR | Valve name: Lotus Valve (nitinol frame with implemented bovine pericardial leaflets) Size of catheter: 21 Fr Lotus Self- or balloon- expanding?: Self- expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 1 (100%) Hemodynamic outcomes: 1) Change in valve area: 0.36 → 1.7 cm^2^ 2) Change in valve gradient: 59 → 23 mm Hg (peak to peak) Clinical status outcomes: Change in NYHA functional class: IV → II 30-day survival: 1 (100%) at 3 mo | Complications: New complete AV block Valve dysfunction: None | Authors state that “successful percutaneous aortic valve replacement can be performed using the new self- expanding and repositionable Lotus valve for treatment of high-risk patients with aortic valve stenosis.”
Chandavimol, McClure, Carere, et al., 2006 18 | Country/countries: Canada Setting: NR Basic design: Case report Study objective(s): NR Duration of follow- up: 12 mo | No. of patients: 1 Age: 85 Sex: Male Medical/functional status: NYHA class III euroSCORE: 30% Surgical indication(s): Severe AS Inclusion criteria: “Surgical risk” deemed excessive by two cardiac surgeons Exclusion criteria: NR | Valve name: Edwards Lifesciences Size of catheter: 24 Fr Self- or balloon- expanding?: Balloon- expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 1 (100%) Hemodynamic outcomes: 1) Change in valve area: 0.7 → 1.8 cm^2^ 2) Change in valve gradient: Mean 58 → 16 mm Hg Clinical status outcomes: Change in NYHA functional class: NR 30-day survival: 1 (100%) at 1 yr | Complications: NR Valve dysfunction: Leak: Trivial paravalvular aortic regurgitation
Cheung, Webb, Wong, et al., 2009 19 | Country/countries: Canada Setting: NR Basic design: Case report Study objective(s): “We report a transcatheter mitral valve-in-valve implant in a patient.” Duration of follow- up: Until death at 47 days | No. of patients: 1 Age: 80 Sex: Male Medical/functional status: NR Surgical indication(s): Symptomatic bioprosthetic mitral stenosis Inclusion criteria: NR Exclusion criteria: NR | Valve name: 26-mm Cribier-Edwards 9000MIS Size of catheter: 33 Fr Self- or balloon- expanding?: Balloon- expanding Implantation approach: Transapical Operator(s): NR | Successful implantation: 1/1 (100%) Hemodynamic outcomes: 1) Method of assessment: TEE C-cath 2) Change in valve area: 0.7 cm^2^ to NR 3) Change in valve gradient: Mean: 17 to 3 mm Hg Clinical status outcomes: Change in NYHA functional class: NR Survival: Pt died 47 days after implantation from multiple organ dysfunction | Complications: Three episodes of ventricular tachycardia requiring defibrillation, and a new LV apical thrombus Major cardiovascular/ cerebrovascular events: Pt sustained embolic stroke after 3 days Valve dysfunction: Leak: No paravalvular or transvalvular mitral regurgitation | Valve-in-valve implantation
Chiam, Koh, Chao, et al., 2009 20 | Country/countries: Singapore Setting: Cath lab Basic design: Case report Study objective(s): “Describe the first ever percutaneous aortic valve implantation for symptomatic severe AS in Asia.” Duration of follow- up: 30 days | No. of patients: 1 Age: 77 Sex: Male Medical/functional status: NYHA class III Surgical indication(s): Severe AS Inclusion criteria: NR Exclusion criteria: NR | Valve name: Sapien THV Size of catheter: 22 Fr Self- or balloon- expanding?: Balloon Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 1/1 (100%) Hemodynamic outcomes: 1) Change in valve area: NR 2) Change in valve gradient: Mean: 57 to 6 mm Hg immediately post- deployment, and 20 mm Hg at 30-day f/u 3) Other: LVEF 46% Clinical status outcomes: NYHA Class I at 30-day f/u Survival: 1/1 (100%) at 30 days | Complications: None reported Major cardiovascular/ cerebrovascular events: None reported Valve dysfunction: Leak: trivial
Clavel, Dumont, Pibarot, et al., 2009 21 | Country/countries: Canada Setting: NR Basic design: Case report Study objective(s): “We report two life- threatening complications associated with percutaneous aortic valve implantation, and we discuss their potential causes and solutions.” Duration of follow- up: Until death at 2 days post-operative | No. of patients: 1 Age: 79 Sex: Male Medical/functional status: NR Surgical indication(s): Low- flow, low-gradient AS Inclusion criteria: NR Exclusion criteria: NR | Valve name: 26-mm Edwards SAPIEN valve Size of catheter: 26 Fr Self- or balloon- expanding?: NR Implantation approach: Transapical Operator(s): NR | Successful implantation: First attempt failed due to severe central aortic regurgitation; second implantation led to postoperative progress for 2 days Hemodynamic outcomes: 1) Method of assessment: TEE TTE 2) Change in valve area: 0.76 cm^2^ to NR 3) Change in valve gradient: Mean: 20 mm Hg to NR Clinical status outcomes: Change in NYHA functional class: NR Survival: Patient developed refractory cardiogenic shock with irreversible metabolic acidosis and disseminated intravascular coagulation, and subsequently died during weaning from cardiopulmonary bypass | Complications: Central aortic regurgitation requiring implantation of second “valve-in-valve” in the same procedure. TWo days after the procedure, both prostheses were found to have migrated into the left ventricle, causing obstruction of the LV outflow tract. Major cardiovascular/ cerebrovascular events: Pt developed cardiogenic shock and death secondary to migration of aortic bioprosthesis into the LV outflow tract Valve dysfunction: Leak: No periprosthetic leak 2 days after the procedure, by TTE
Cribier, Eltchaninoff, Tron, et al., 2004 22 and Eltchaninoff, Tron, and Cribier, 2003 23 and Cribier, Eltchaninoff, Bash, et al., 2002 24 | Country/countries: France Setting: Cath lab Basic design: Case series Study objective(s): Assess the results of PHV implantation in non-surgical patients with end-stage calcific aortic stenosis Duration of follow- up: 8 to 18 wk | No. of patients: 6 (1 death at surgery, 5 evaluable) Age: 75 ± 12 (57 to 91) Sex: Female: 1 (17%) Male: 5 (83%) Medical/functional status: NYHA class IV Surgical indication(s): End-stage aortic stenosis Inclusion criteria: - Severe calcific aortic stenosis and multiple comorbidities - Declined for surgery by cardiac surgeons owing to hemodynamic instability and/or comorbidities - Aortic valve area ≤ 0.6 cm^2^ Exclusion criteria: NR | Valve name: Percutaneous Valve Technologies, Inc. Size of catheter: 22 to 23 mm Self- or balloon- expanding?: Balloon- expanding Implantation approach: Transfemoral anterograde Operator(s): NR | Successful implantation: 5/6 (83%) Hemodynamic outcomes: 1) Change in valve area: Mean 0.49 ± 0.08 → 1.66 ± 0.13 cm^2^ 2) Change in valve gradient: Mean 38 ± 11 → 5.6 ±3.4 mm Hg 3) Other – EF: Mean 24 ± 9.5 → 41 ± 12% Clinical status outcomes: Change in NYHA functional class: NR 30-day survival: 1) 2 (33%) at 8 wk 2) Deaths (intra-operative to 18 wk): - Complications of leg amputation (n = 1) - Acute abdominal syndrome (n = 1) - Rectal cancer (n = 1) | Complications: Hemodynamic collapse: 2 (33%) Valve dysfunction: Leak: - Severe paravalvular AR 2/5 (40%) - Mild paravalvular AR 3/5 (60%) Migration: 1/6 (17%) | 2-patient overlap between Cribier, Eltchaninoff, Tron, et al., 2004^22^ and Cribier, Eltchaninoff, Tron, et al., 2006^25^ (i.e., the same 2 patients are described in both study reports)
Cribier, Eltchaninoff, Tron, et al., 2006 25 | Country/countries: France Setting: NR Basic design: Case series Study objective(s): Primary: Study the feasibility, safety, efficacy, and durability of PHV implantation in the aortic position Secondary: Obtain data regarding the efficacy and durability of the PHV Duration of follow- up: Up to 26 mo | No. of patients: 36 enrolled; 33 underwent procedure (1 death prior to procedure, 1 death during pre-dilation, 1 procedure cancelled because annulus too large) Age: 80 ± 7 (62 to 91) Sex: Female: 15 (43%) Male: 21 (57%) Medical/functional status: NYHA class IV euroSCORE: 12 ± 2% Surgical indication(s): Inoperable AS Inclusion criteria: - Severe aortic valve stenosis with associated symptoms that were expected to benefit from isolated valve replacement - Formally declined for surgery by two independent cardiac surgeons on basis of high risk for surgery - Severe comorbidities - Aortic valve area ≤ 0.7 cm^2^ - NYHA functional class IV Exclusion criteria: - Vascular disease that precluded access - Severe deformation of the chest - Intracardiac thrombus - Unprotected stenosis of the left main coronary artery not amenable to percutaneous intervention - MI within 7 days - Prosthetic heart valves - Active infection - Leukopenia - Coagulopathy - Active bleeding - Acute anemia - Pts who could not be fully dilated with a 23 mm aortic valvuloplasty balloon and pts with a native aortic valve annulus size > 24 mm or < 19 mm were also excluded | Valve name: Percutaneous Valve Technologies, Inc. (later became known as CoreValve) Size of catheter: NR Self- or balloon- expanding?: NR Implantation approach: Transfemoral retrograde: 7 Transfemoral antegrade: 26 Aborted retrograde to antegrade: 1 Operator(s): NR | Successful implantation: 27/35 taken to cath lab (77%) 27/33 PHV placement attempted (82%) 2 procedures aborted; 2 acute PHV migrations; 3 failures to cross Hemodynamic outcomes: 1) Change in valve area: 0.6 ± 0.11 → 1.7 ± 0.1 cm^2^ (p < 0.0001) 2) Change in valve gradient: Mean 37 ± 13 → 9 ± 2 mm Hg (p < 0.0001) 3) Other – LVEF: 45 ± 18 → 53 ± 14% at 1 wk (p = 0.02) Clinical status outcomes: Change in NYHA functional class (for 30-day survivors): To class I: 5 (24%) To class II: 14 (67%) To class III: 2 (10%) No improvement: 0% Survival: 1) 21 (78%) among patients with successful implantation at 30 days; 17 (63%) at 6 mo 2) Deaths associated with the procedure: - Tamponade (n = 2) - Brain death post- resuscitation (n = 1) - Ventriculararrhythmia (n = 1) - Unknown etiology (n = 1) | Complications: Stroke: 1 (3%) Valve dysfunction: Leak: Paravalvular AR 10 (37%) Grade 1 12 (44%) Grade 2 5 (19%) Grade 3 PHV migrations: 2 | 2-patient overlap with Cribier, Eltchaninoff, Tron, et al., 2004^22^ (i.e., the same 2 patients are described in both study reports)
Dumonteil, Marcheix, Berthoumieu et al., 2009 26 | Country/countries: France Setting: NR Basic design: Case report Study objective(s): NR Duration of follow- up: 1 month | No. of patients: 1 Age: 82 Sex: Female Medical/functional status: NR Surgical indication(s): Severe aortic stenosis, with a history of mitral valve replacement 25 years prior Inclusion criteria: NR Exclusion criteria: NR | Valve name: Edwards Sapien Size of catheter: NR Self- or balloon- expanding?: Balloon- expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 1/1 (100%) Hemodynamic outcomes: 1) Method of assessment: TEE Fluoroscopy 2) Change in valve area: NR 3) Change in valve gradient: NR. “Normal mitral and aortic prosthesis function with only grade 1 aortic prosthesis leak.” Clinical status outcomes: 1) Change in NYHA functional class: Class II at 1 month Survival: 1/1 (100%) at 1 month | Complications of procedure: NR Major cardiovascular/ cerebrovascular events: NR Valve dysfunction: Grade 1 aortic prosthesis leak
Dvir, Assali, Vaknin, et al., 2009 27 | Country/countries: Israel Setting: NR Basic design: Case report Study objective(s): “We report a patient treated by this novel method, discuss and assess how it is implanted, report the findings conducted to date, and suggest future directions for percutaneous treatment of aortic valve disease.” Duration of follow- up: 4 months | No. of patients: 1 Age: 87 Sex: Male Medical/functional status: NR Surgical indication(s): Deteriorating functional capacity secondary to weakness and dyspnea Inclusion criteria: NR Exclusion criteria: NR | Valve name: Edwards SAPIEN valve Size of catheter: 24 Fr Self- or balloon- expanding?: Balloon- expanding Implantation approach: Transfemoral retrograde Operator(s): A multidisciplinary team of experts in echocardiography, intensive care, vascular surgery, radiology, cardiothoracic surgery, and invasive cardiology. | Successful implantation: 1/1 (100%) Hemodynamic outcomes: 1) Method of assessment: TEE C-cath 2) Change in valve area: 0.55 to 1.7 cm^2^ 3) Change in valve gradient: 101/62 to 33/16 mm Hg intraoperatively Clinical status outcomes: Change in NYHA functional class: NR Survival: 1/1 (100%) at 4 months | Complications: NR Major cardiovascular/ cerebrovascular events: NR Valve dysfunction: Leak: No paravalvular leakage immediately post-procedure
Falk, Schwammenthal, Kempfert, et al., 2009 28 | Country/countries: Germany and Israel Setting: Surgical hybrid suite Basic design: Case report Study objective(s): “Here we report implantation of this new valve in a patient.” Duration of follow- up: 19 days | No. of patients: 1 Age: 85 Sex: Female Medical/functional status: NR Surgical indication(s): Symptomatic AS Inclusion criteria: NR Exclusion criteria: NR | Valve name: Ventor Embracer Valve Size of catheter: 27 Fr Self- or balloon- expanding?: Self- expanding Implantation approach: Transapical Operator(s): NR | Successful implantation: 1/1 (100%) Hemodynamic outcomes: 1) Method of assessment: Echocardiogram 2) Change in valve area: NR 3) Change in valve gradient: Mean: NR to 4 mm Hg Peak: NR to 8 mm Hg Clinical status outcomes: Change in NYHA functional class: NR Survival: Alive at discharge on day 19; no further f/u reported | Complications: NR Major cardiovascular/ cerebrovascular events: NR Valve dysfunction: Leak: Minimal paravalvular leak (grade < 1)
Geist, Sherif, and Khattab, 2009 29 | Country/countries: Germany Setting: NR Basic design: Case report Study objective(s): NR Duration of follow- up: 3 months | No. of patients: 1 Age: 79 Sex: Female Medical/functional status: NR Surgical indication(s): Non-ST elevation myocardial infarction Inclusion criteria: NR Exclusion criteria: NR | Valve name: CoreValve ReValving System Size of catheter: 18 Fr Self- or balloon- expanding?: Self- expanding Implantation approach: NR Operator(s): NR | Successful implantation: 1/1, but the article deals with successful coronary artery intervention 3 mo after valve implantation Hemodynamic outcomes: 1) Method of assessment: NR 2) Change in valve area: NR 3) Change in valve gradient: Peak: 60 to 5 mm Hg Clinical status outcomes: Change in NYHA functional class: NR Survival: 1/1 (100%) at 3 months | Complications: NR Major cardiovascular/ cerebrovascular events: NR Valve dysfunction: NR
Grube, Buellesfeld, Mueller, et al., 2008 30 | Country/countries: Germany Setting: NR Basic design: Prospective single site safety and performance study Study objective(s): “To demonstrate the progress among the various CoreValve Revalving device generations and to evaluate the current feasibility, safety, and efficacy status up to 12 months postimplantation, particularly of the third generation 18F CoreValve ReValving prosthesis compared with device generations 1 (25F) and 2 (21F)” Duration of follow- up: NR | No. of patients: 136 Age: 82 ± 7 Sex: Female: 79 (58%) Male: 57 (42%) Surgical indication(s): AS Inclusion criteria: - Severe AS (area < 1cm^2^) and - ≥ 80 yr with a logistic euroSCORE (mortality) ≥ 20% (21 Fr group) - or ≥ 75 yr with a logistic euroSCORE (mortality) ≥ 15% (18 Fr group) - or ≥ 65 yr plus additional prespecified risk factors Exclusion criteria: - Hypersensitivity or contraindication to any study medication - Sepsis or active endocarditis - Excessive femoral, iliac or aortic atherosclerosis | Valve name: CoreValve ReValving system Size of catheter: 25 Fr (n = 10) 21 Fr (n = 24) 18 Fr (n = 102) Self- or balloon- expanding?: Self- expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: Generation 1: 7/10 (70%) Generation 2: 17/24 (71%) Generation 3: 93/102 (92%) Hemodynamic outcomes: 1) Change in valve area: NR 2) Change in valve gradient: 41.6 + 16.4 → 8.1 + 3.8 mm Hg in generation 3 Clinical status outcomes: Change in NYHA functional class: 3.3 ± 0.5 → 1.7 ± 0.7 30-day survival: Generation 1: 6/10 (60%) Generation 2: 22/24 (92%) Generation 3: 91/102 (89%) 12-month survival: Generation 1: 60% Generation 2: 79% Generation 3: 84% | Procedural major adverse CV and cerebral events: Generation 1: 20.0% Generation 2: 16.7% Generation 3: 3.9% Complications: 3 (2%) incorrect valve positioning, requiring deployment of 2nd prosthesis Valve dysfunction: Worsening of preinterventional AR in 33 patients (26%). Of these, 2 had postintervention AR of grade 3+. No grade 4+ AR. | 10-patient overlap with Grube, Laborde, Gerckens, et al., 2006^31^ and Grube, Schuler, Buellesfeld, et al., 2007^32^ (i.e., the same 10 patients are described in all 3 study reports) plus An additional 4- patient overlap with Grube, Schuler, Buellesfeld, et al., 2007^32^
Grube, Laborde, Gerckens, et al., 2006 31 | Country/countries: Germany Setting: NR Basic design: Single-site case series Study objective(s): “To evaluate the feasibility and safety of implantation of the self-expanding CoreValve aortic valve prosthesis in high-risk patients with aortic valve disease using a retrograde percutaneous approach.” Duration of follow- up: Up to 1 yr | No. of patients: 25 Age: 80 (range 68–94) Sex: Female: 20 (80%) Male: 5 (20%) Surgical indication(s): AS Inclusion criteria: - Severe AS (area < 1cm^2^) - Aortic valve annulus diameter ≥ 20 and ≤ 23 mm) - Contraindication to surgery Exclusion criteria: - Hypersensitivity or contraindication to any study medication - Sepsis or active endocarditis - Excessive femoral, iliac or aortic atherosclerosis | Valve name: CoreValve ReValving system Size of catheter: 24 Fr (n = 10) 21 Fr (n = 15) Self- or balloon- expanding?: Self- expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 22/25 (88%) Hemodynamic outcomes: 1) Change in valve area: NR 2) Change in valve gradient: 44.2 ± 10.8 → 12.4 ± 3.0 Clinical status outcomes: NR 30-day survival: 20/25 (80%) | Complications: - Urgent open heart surgery (n = 1) - Severe AI - Left ventricle perforation - Hemodynamic failure - Disseminated intravascular coagulation Valve dysfunction: Valve leakage: Grade 0: 10 Grade 1+: 7 Grade 2+: 4 Grade 3–4+: 0 | 10-patient overlap with Grube, Buellesfeld, Mueller, et al., 2008^30^ and Grube, Schuler, Buellesfeld, et al., 2007^32^ (i.e., the same 10 patients are described in all 3 study reports)
Grube, Laborde, Zickmann, et al., 2005 33 | Country/countries: Germany Setting: NR Basic design: Case report Study objective(s): NR Duration of follow- up: 2 wk | No. of patients: 1 Age: 73 Sex: Female Medical/functional status: NYHA class IV Surgical indication(s): Severe symptomatic AS Inclusion criteria: Surgical valve replacement had been declined for the pt because of comorbidities, including previous bypass surgery Exclusion criteria: NR | Valve name: CoreValve, composed of three bovine pericardial leaflets inserted within a self-expanding nitinol stent Size of catheter: 25 Fr Self- or balloon- expanding?: Self- expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 1 (100%) Hemodynamic outcomes: 1) Change in valve area: NR 2) Change in valve gradient: Mean 45 → 8 mm Hg 3) Other – EF: 45 → 76% Clinical status outcomes: Change in NYHA functional class: IV → II 30-day survival: 1 (100%) | Complications: None Valve dysfunction: None
Grube, Schuler, Buellesfeld, et al., 2007 32 | Country/countries: Germany and Canada Setting: NR Basic design: Prospective multicenter, single- arm safety and performance study Study objective(s): To determine both the procedural performance and safety of percutaneous implantation of the second (21-Fr) and third (18-Fr) generation CoreValve aortic valve prosthesis Duration of follow- up: 30 days | No. of patients: 86 50 = 21 Fr 36 = 18 Fr Age: 21-Fr: Mean 81± 5 yr 18-Fr: Mean 83 ± 7 yr Sex: Female: 56 (65%) Male: 30 (35%) Medical/functional status: 71 (83%) NYHA class III or IV Logistic euroSCORE (mortality): 21-F: 23 ± 14% 18-F: 19 ± 11% Surgical indication(s): Symptomatic severe AS Inclusion criteria: - Severe AS (area < 1 cm^2^) - And ≥ 80 yr with a logistic euroSCORE (mortality) ≥ 20% (21-F group) - Or ≥ 75 yr with a logistic euroSCORE (mortality) ≥ 15% (18-F group) - Or ≥ 65 yr plus additional prespecified risk factors Exclusion criteria: - Hypersensitivity or contraindication to any study medication - Sepsis or active endocarditis - Excessive femoral, iliac or aortic atherosclerosis | Valve name: CoreValve Size of catheter: 21 Fr (2^nd^ generation) 18 Fr (3^rd^ generation) Self- or balloon- expanding?: Self- expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: Acute device success 76/86 (88%) Hemodynamic outcomes: 1) Change in valve area: NR 2) Change in valve gradient: NR Clinical status outcomes: Change in NYHA functional class: Mean class 2.85 ± 0.73 → 1.85 ± 0.6 (p < 0.0001) 30-day survival: 76 (88%) at 30 days | Complications: - Conversion to operative valve placement due to misplacement of valve: 6 - Stroke: 9 (10%) - Cardiac tamponade: 9/64 (14%) - Death or MI or tamponade or stroke or conversion to surgery/valvulo- plasty or emerging DCI: 22 (26%) Valve dysfunction: Leak (paravalvular): - Grade 3+ or 4+ AR: 0 - Worsening to grade 2+: 15 (20%) - Worsening to grade 1+: 11 (14%) | 10-patient overlap with Grube, Laborde, Gerckens, et al., 2006^31^ and Grube, Buellesfeld, Mueller, et al., 2008^30^ (i.e., the same 10 patients are described in all 3 study reports) plus An additional 4- patient overlap with Grube, Buellesfeld, Mueller, et al., 2008^30^ Authors state that “percutaneous valve replacement with the CoreValve revalving system for selected patients with severe AS provides an encouraging device success rate, results in marked hemodynamic and clinical improvement, and is associated with a comparably low acute and 30-day mortality rate in this high-risk population.”
Hanzel, Harrity, Schreiber, et al., 2005 34 | Country/countries: United States Setting: NR Basic design: Case report Study objective(s): NR Duration of follow- up: 5 days (until death) | No. of patients: 1 Age: 84 Sex: Male Medical/functional status: NYHA class IV Surgical indication(s): Critical AS Inclusion criteria: Deemed too high-risk for surgical aortic valve replacement by two surgeons Exclusion criteria: NR | Valve name: Percutaneous Valve Technologies (trileaflet bovine pericardial valve mounted within a stainless steel tubular-slotted stent) Size of catheter: 24 Fr Self- or balloon- expanding?: Balloon- expanding Implantation approach: Transfemoral retrograde (successful implantation) Transfemoral antegrade (unsuccessful attempt) Operator(s): NR | Successful implantation: 1 (100%) Hemodynamic outcomes: 1) Change in valve area: 0.55 → 1.7 cm^2^ 2) Change in valve gradient: 45 → 4 mm Hg 3) Other – EF: 20 → 20% Clinical status outcomes: Change in NYHA functional class: NR 30-day survival: 0 (0%) at 30 days | Complications: Day 1: Pt developed pulseless electrical activity requiring chest compressions, removal of guidewire, intubation, vasoactive drugs, and intra-aortic balloon pump insertion; antegrade approach abandoned; AV crossed retrograde Day 3: Pt developed VT requiring 1 electrical shock Day 4: Pt developed worsening hypotension requiring addition of norepinephrine and neosynephrine to dopamine and dobutamine Day 5: Pt developed pulseless electrical activity, and was resuscitated after 25 min; decision made to withhold further resuscitative efforts, and patient died Valve dysfunction: Leak: Mild/moderate paravalvular AR
Himbert, Descoutures, Al-Attar, et al. 2009 35 | Country/countries: France Setting: NR Basic design: Case series Study objective(s): “We sought to describe the results of a strategy offering either transfemoral or transapical aortic valve implantation (TAVI) in high-risk patients with severe aortic stenosis.” Duration of follow-up: 10 months (SD 6); range 1–27 | No. of patients: 75 (51 transfemoral, 24 transapical) Age: 82 (SD 8) Sex: Female n=34 (45%) Male n=43 (55%) Medical/functional status: NYHA class II: 4 (5%) III: 40 (53%) IV: 32 (41%) Surgical indication(s): AS Inclusion criteria: Among all patients with severe symptomatic AS consecutively referred for TAVI by primary or tertiary hospitals or by independent cardiologists, with a high surgical risk or contraindications to surgical aortic valve replacement. Inclusion criteria included EuroSCORE ≥ 20% or STS-PROM ≥ 10%, life expectancy > 1yr, anatomy suitable for intervention, and no need for CABG. Exclusion criteria: NR | Valve name: Edwards-SAPIEN Size of catheter: NR Self-or balloon-expanding?: Balloon Implantation approach: Transfemoral retrograde as first option; transapical approach used when there were contraindications to the transfemoral route Operator(s): Cardiac surgeon | Successful implantation: Overall: 70/75 (93%) Transfemoral: 46/51 (90%) Transapical: 24/24 (100%) Hemodynamic outcomes: 1) Method of assessment: TTE 2) Change in valve area: NR 3) Change in valve gradient: NR Clinical status outcomes: 1) Change in NYHA functional class: NYHA functional class among survivors at last f/u: I: 20 (33%) II: 35 (57%) III: 6 (10%) 2) Survival (at 30 days: Overall: 69/75 (92%) Transfemoral: 47/51 (92%) Transapical: 22/24 (92%) | Complications: Hemopericardium in 1 pt from perforation of left ventricle, leading to intraprocedural death Major cardiovascular/cereb rovascular events: Stroke: n = 3 (all in transfemoral group) Valve dysfunction: Leak: Grade II or greater: 13 (17%) Grade III or greater: 4 (5%) Redilation for paravalvular leak: 5 (7%) AV blocks requiring pacemaker: 4 (5%) Emergent implantation of a second valve (“valve-in-valve”) in 1 pt Second valve implanted in a higher position because of misplacement of first valve in 2 pts Iliac dissections: 4 (5%) Tamponade: 4 (5%)
Kapadia, Svensson, and Tuzcu, 2009 36 | Country/countries: United States Setting: NR Basic design: Case report Study objective(s): “We report an uncommon complication of left main trunk occlusion with deployment of the valve and its successful percutaneous management with clinical follow-up.” Duration of follow-up: 18 months | No. of patients: 1 Age: 82 Sex: Female Medical/functional status: NR Surgical indication(s): Severe aortic stenosis, presenting with NSTEMI and heart failure Inclusion criteria: NR Exclusion criteria: NR | Valve name: NR Size of catheter: NR Self-or balloon-expanding?: Balloon-expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 1/1 (100%) Hemodynamic outcomes: NR Clinical status outcomes: Change in NYHA functional class: NR Survival: 1/1 (100%) at 18 months | Complications of procedure: Left main trunk occlusion Major cardiovascular/ cerebrovascular events: Left main trunk occlusion Valve dysfunction: NR
Klaaborg, Egeblad, Jakobsen, et al., 2009 37 | Country/countries: Denmark Setting: NR Basic design: Case report Study objective(s): “We report transapical treatment of a stenosed 21 mm Mitroflow aortic valve prosthesis using the Edwards SAPIEN THV.” Duration of follow-up: 2 weeks post-procedure; no further f/u data reported | No. of patients: 1 Age: 82 Sex: Female Medical/functional status: NR Surgical indication(s): Severe stenosis, shortness of breath, chest pain, overt heart failure Inclusion criteria: NR Exclusion criteria: NR | Valve name: Original: 21-mm Mitroflow Replacement: 23-mm Edwards SAPIEN THV Size of catheter: 26 Fr Self-or balloon-expanding?: Balloon-expanding Implantation approach: Transapical Operator(s): NR | Successful implantation: 1/1 (100%) Hemodynamic outcomes: 1) Method of assessment: TTE 2) Change in valve area: 0.4 to 1.0 cm^2^ 3) Change in valve gradient: Peak: 100 to 40 mm Hg Clinical status outcomes: Change in NYHA functional class: NR Survival: Alive at discharge 2 weeks after the procedure; no further f/u reported | Complications: NR Major cardiovascular/ cerebrovascular events: NR Valve dysfunction: Leak: Mild central aortic valve regurgitation
Kolettis, Spargias, and Stavridis, 2009 38 | Country/countries: Greece Setting: Cardiac cath lab Basic design: Case report Study objective(s): “We present a case of on-pump coronary artery bypass grafting with beating heart, combined with transapical aortic valve implantation, in a young man with porcelain aorta, severe AS and critical stenosis of the left main coronary artery.” Duration of follow-up: 6 days | No. of patients: 1 Age: 48 Sex: Male Medical/functional status: NR Surgical indication(s): Severe AS, left main coronary artery disease, and porcelain aorta Inclusion criteria: NR Exclusion criteria: NR | Valve name: 23-mm Edwards SAPIEN pericardial stented xenograft prosthesis Size of catheter: Self-or balloon-expanding?: Balloon-expanding Implantation approach: Transapical (in combination with CABG via sternotomy) Operator(s): Interventional cardiologist | Successful implantation: 1/1 (100%) Hemodynamic outcomes: 1) Method of assessment: TEE C-cath 2) Change in valve area: NR 3) Change in valve gradient: NR Clinical status outcomes: Change in NYHA functional class: NR Survival: Alive at discharge on day 6 | Complications: NR Major cardiovascular/ cerebrovascular events: NR Valve dysfunction: Leak: Mild aortic insufficiency without any paravalvular leak | Postoperative echocardiography revealed mild aortic insufficiency without any paravalvular leak
Lamarche, Cartier, Denault, et al., 2007 39 | Country/countries: Canada Setting: NR Basic design: Case report Study objective(s): NR Duration of follow-up: 3 mo | No. of patients: 1 Age: 64 Sex: Female Medical/functional status: NYHA class IV Parsonnet score 35 Surgical indication(s): -Critical AS -Idiopathic pulmonary fibrosis Inclusion criteria: Refused for AVR surgery Exclusion criteria: NR | Valve name: ReValving System (CoreValve, Paris) Size of catheter: 21 Fr Self-or balloon-expanding?: Self-expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 1 (100%) Hemodynamic outcomes: 1) Change in valve area: 0.61 → 1.4 cm^2^ 2) Change in valve gradient: NR 3) Other – LVEF: 20 → 35% Clinical status outcomes: Change in NYHA functional class: NR Survival: 1 (100%) at 3 mo | Complications: None Valve dysfunction: Leak: Trace paravalvular
Lange, Schreiber, Gotz, et al., 2007 40 | Country/countries: Germany Setting: Hybrid operation theater Basic design: Case report Study objective(s): NR Duration of follow-up: 10 days | No. of patients: 1 Age: 87 Sex: Female Medical/functional status: NYHA class III Logistic euroSCORE (mortality) 36% euroSCORE 13 Surgical indication(s): NR Inclusion criteria: NR Exclusion criteria: NR | Valve name: CoreValve TAVR ReValving (Irvine, CA) Size of catheter: 18 Fr sheath Self-or balloon-expanding?: Self-expanding Implantation approach: Transapical Operator(s): NR | Successful implantation: 1 (100%) Hemodynamic outcomes: 1) Change in valve area: NR 2) Change in valve gradient: Peak gradient of 100 mm Hg to mean gradient of 15 mm Hg 3) Other – EF: Unchanged: 50% Clinical status outcomes: Change in NYHA functional class: NR Survival: 1 (100%) at 10 days | Complications: None Valve dysfunction: Leak: Trace paravalvular leak
Lichtenstein, Cheung, Ye, et al., 2006 41 and Ye, Cheung, Lichtenstein, et al., 2007 42 | Country/countries: Canada Setting: Operating room with fluoroscopy Basic design: Case series Study objective(s): NR Duration of follow-up: 6 mo | No. of patients: 7 Age: 77± 10 Sex: Female: 2 (29%) Male: 5 (71%) Medical/functional status: NYHA class II: 2 (29%) NYHA class III: 4 (58%) NYHA class IV: 1 (13%) Logistic euroSCORE (mortality): 31±23% Surgical indication(s): Symptomatic AS Inclusion criteria: Judged to be at unacceptably high risk for routine open-heart AVR with CPB because of significant comorbidity Exclusion criteria: NR | Valve name: Cribier-Edwards Valve (Edwards Lifesciences, Inc.) equine pericardial trileaflet valve Size of catheter: 24 Fr Self-or balloon-expanding?: Balloon-expanding Implantation approach: Transapical Operator(s): NR | Successful implantation: 7 (100%) Hemodynamic outcomes: 1) Change in valve area: 0.7 ± 0.3 → 1.8 ± 0.7 cm^2^ 2) Change in valve gradient: Mean 32 ± 8 → 10 ± 5 mm Hg at 1 mo 3) Other: LVEF 49 ± 9% → 52 ± 13% No change in valve function after procedure to one month later Clinical status outcomes: Change in NYHA functional class: “Improved” in 4 “Unchanged” in 1 30-day survival: 1) 6/7 (86%) 2) 4/7 (57%) at 6 mo 3) 1 death from pneumonia on day 12 4) 1 death from lung disease 5) 1 death from cancer | Complications: None Valve dysfunction: Leak: paravalvular leak: Trivial: 4 (59%) Mild: 2 (29%) Moderate: 1 (14%)
Marcheix, Lamarche, Berry, et al., 2007 43 | Country/countries: Canada Setting: Sterile cardiologic interventional suite Basic design: Case series Study objective(s): Report the experience with retrograde endovascular bioprosthesis implantation with brief cardiopulmonary bypass support in high-risk older patients Duration of follow-up: 1 mo | No. of patients: 10 Age: Mean 81 (64 to 85) Sex: Female: 5 (50%) Male: 5 (50%) Medical/functional status: NYHA class III: 7 (70%) NYHA class IV: 3 (30%) Median euroSCORE: 32% (21% to 40%) Surgical indication(s): -Severe AS -Deemed by 2 cardiothoracic surgeons to be at prohibitively high surgical risk for conventional open chest AVR Inclusion criteria: High or prohibitive risk with conventional surgery Exclusion criteria: NR | Valve name: CoreValve (Paris) Size of catheter: 21 Fr Self-or balloon-expanding?: Self-expanding Implantation approach: Retrograde Operator(s): NR | Successful implantation: 10 (100%) Hemodynamic outcomes: 1) Change in valve area: 0.57 → 1.2 cm^2^ 2) Change in valve gradient: Mean 51 ± 19 → 11 ± 3 mm Hg Clinical status outcomes: Change in NYHA functional class: Median III → II (p = 0.01) 30-day survival: 7/10 (70%) Deaths: -2 from stroke; -1 in hospital (cause NR) | Complications: -Vascular access site complication: 3 (30%) -Confusion: 3 (30%) -Respiratory infection: 1 (10%) -Hemopericardium requiring pericardiocentesis: 1 (10%) -Stroke: 2 (20%) -Acute renal failure: 1 (10%) -Non-sustained atrial fibrillation: 2 (20%) -Major bleeding: 2 (20%) -Ophthalmoplegia: 1(10%) Valve dysfunction: Leak: -Mild intraprosthesis 5 (50%) -Grade 1 periprosthetic leak 7 (70%) -Grade 2 periprosthetic leak 1 (10%) Need for re-intervention: 0; 2 patients required reoperation, but not cardiac
Moreno, Dobarro, Lopez de Sa, et al., 2009 44 | Country/countries: Spain Setting: NR Basic design: Case report Study objective(s): NR Duration of follow-up: 3 days | No. of patients: 1 Age: 79 Sex: Female Medical/functional status: NR Surgical indication(s): Symptomatic severe AS Inclusion criteria: NR Exclusion criteria: NR | Valve name: 26-mm Edwards SAPIEN Size of catheter: NR Self-or balloon-expanding?: Balloon-expanding Implantation approach: NR Operator(s): NR | Successful implantation: Without complication except complete atrialventricular block requiring transvenous pacemaker stimulation Hemodynamic outcomes: NR Clinical status outcomes: Change in NYHA functional class: NR Survival: Sudden cardiac death 3 days post-op (caused by RV perforation) | Complications: AV block requiring transvenous pacemaker Major cardiovascular/ cerebrovascular events: NR Valve dysfunction: NR
Ng, van der Kley, Delgado, et al., 2009 45 | Country/countries: The Netherlands Setting: NR Basic design: Case report Study objective(s): “We would like to share our experience with an 82 y/o man referred for percutaneous aortic valve replacement for treatment of grade 3 paravalvular aortic regurgitation with a ‘valve-in-valve’ procedure.” Duration of follow-up: 30 days | No. of patients: 1 Age: 82 Sex: Male Medical/functional status: NYHA class III Surgical indication(s): NR Inclusion criteria: Patient had history of aortic valve replacement with a Medtronic Freestyle stentless aortic valve Exclusion criteria: NR | Valve name: CoreValve Revalving System Size of catheter: NR Self-or balloon-expanding?: NR Implantation approach: Transapical Operator(s): NR | Successful implantation: First attempt unsuccessful because of increased aortic regurgitation severity due to nondeployment of a single aortic cusp. Second implantation successful. Hemodynamic outcomes: Method of assessment: TTE Cardiac computed tomography Change in valve area: NR Change in valve gradient: NR Clinical status outcomes: Change in NYHA functional class: NR Survival: 1/1 (100%) at 30 days | Complications: NR Major cardiovascular/ cerebrovascular events: NR Valve dysfunction: Leak: “Minimal” residual paravalvular leak and mild central aortic regurgitation
Paniagua, Condado, Besso, et al., 2005 46 | Country/countries: Venezuela Setting: Cath lab Basic design: Case report Study objective(s): NR Duration of follow-up: 5 days (until death) | No. of patients: 1 Age: 62 Sex: Male Medical/functional status: Clinical description consistent with NYHA class IV Surgical indication(s): Inoperable calcific aortic stenosis and multiple severe comorbidities, including pulmonary edema, CHF, and pulmonary HTN Inclusion criteria: Pt was declined by three surgical groups because of low EF, comorbidities, and generally hopeless situation Exclusion criteria: NR | Valve name: Paniagua Heart Valve (Endoluminal Technology Research, Miami, FL) Size of catheter: NR Self-or balloon-expanding?: Balloon-expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 1 (100%) Hemodynamic outcomes: 1) Change in valve area: 0.6 → 1.6 cm^2^ 2) Change in valve gradient: 36 → < 5 mm Hg 3) Other – LVEF: 15% unchanged Clinical status outcomes: Change in NYHA functional class: NR 30-day survival: 0% at 30 days Death on day 5 from reoperation failure | Complications: -Cardiac arrest requiring resuscitation and intubation -Complete atrioventricular block -Suspected pulmonary embolism Valve dysfunction: Leak: Mild paravalvular leak
Piazza, Schultz, de Jaegere, et al., 2009 47 | Country/countries: The Netherlands Setting: NR Basic design: Case series Study objective(s): To evaluate the procedural, imaging, and clinical outcomes of patients who underwent transcatheter valve-in-valve implantation with two self-expanding aortic valve bioprostheses during the same procedure Duration of follow-up: Up to 351 days | No. of patients: 5 Age: Mean: 79 Range: 73-84 Sex: Female: 2 (40%) Male: 3 (60%) Medical/functional status: 79 yo female – NYHA IV 73 yo male – NYHA IV 79 yo male – NYHA III 80 yo male – NYHA IV 84 yo female – NYHA IV Surgical indication(s): Dyspnea, angina Inclusion criteria: 5 case reports of valve-in-valve implantation, from a series of 59 patients (54 of whom did not undergo a valve-in-valve procedure) Exclusion criteria: Patients in whom 2 sequential valves were implanted. | Valve name: CoreValve Revalving System Size of catheter: NR Self-or balloon-expanding?: Self-expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: Not applicable, because only patients with failure of implantation of a first valve are included in this report. Of the 5 patients who underwent valve-in-valve implantation, 5/5 (100%) second valves were successfully implanted. Hemodynamic outcomes: Method of assessment: Computed tomography TTE Change in valve area: NR Change in valve gradient: NR Clinical status outcomes: Change in NYHA functional class: NR Survival: 79 yo female – died day 6 from septic shock and renal failure 73 yo male – alive at 351 days 79 yo female – alive at 316 days 80 yo male – alive at 64 days 84 yo female – alive at 8 days | Complications: 79 yo female – Cardiac tamponade (LAA and LV perforation) 79 yo male – Stroke and PPM for complete AVB 80 yo male Recurrent SOB; ↑ peak TAVG to 49 mm Hg 73 yo male & 84 yo female – no complications Major cardiovascular/ cerebrovascular events: See above Valve dysfunction: NR
Piazza, Serruys, and de Jaegere, 2009 48 | Country/countries: The Netherlands Setting: NR Basic design: Case reports Study objective(s): To describe the feasibility of the combination of percutaneous coronary intervention and percutaneous aortic valve implantation with peripheral left ventricular assist device (TandemHeart) support Duration of follow-up: 4–86 days | No. of patients: 3 Age: Mean: 87.3 Range: 81–93 Sex: Female 3 (100%) Medical/functional status: 1 pt – NYHA III 2 pts – NYHA IV Surgical indication(s): Dyspnea, angina Inclusion criteria: NR Exclusion criteria: NR | Valve name: CoreValve Revalving System Size of catheter: 18 Fr Self-or balloon-expanding?: Self-expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 3/3 (100%) Hemodynamic outcomes: Method of assessment: Intracardiac echocardiography Change in valve area: Pt #1: 0.7 to 1.4 cm^2^ Pt #2: Baseline NR to 1.7 cm^2^ Pt. #3: NR Change in mean valve gradient: Pt #1: 20 to 9 mm Hg Pt #2: Baseline NR to 8 mm Hg Pt. #3: NR Clinical status outcomes: Change in NYHA functional class: NR Survival: Alive at 86, 57, and 4 days follow-up, respectively | Complications: NR Major cardiovascular/ cerebrovascular events: NR Valve dysfunction: NR
Rodés-Cabau, Dumont, De LaRochellière, et al., 2008 49 | Country/countries: Canada Setting: Cath lab for transfemoral procedure, and operating room for transapical procedure Basic design: Case series Study objective(s): “To evaluate the results of…a multidisciplinary percutaneous aortic valve implantation program, focusing on patient and approach selection criteria, procedural results, and complications, as well as mid-term follow-up” Duration of follow-up: Median 6 mo | No. of patients: 24 enrolled, but 2 died awaiting the procedure, for actual sample size of 22 Age: 84 (range 62– 91) Sex: Female: 12 (55%), Male: 10 (45%) Medical/functional status: NYHA IV Surgical indication(s): Mixed aortic valve disease with severe AR and moderate AS. Patient was a candidate for surgical AVR, but she declined. Inclusion criteria: All patients who underwent the procedure at the study center from Apr 2007 to Jan 2008 Exclusion criteria: NR | Valve name: Edwards-Sapien. 23 mm (n = 12) 26 mm (n = 10) Size of catheter: 22 Fr (n = 12) 24 Fr (n = 10) Self-or balloon-expanding?: Balloon-expanding Implantation approach: Transfemoral retrograde (n = 10); transapical (n = 11); aborted transfemoral to transapical (n = 1) Operator(s): Cardiac surgeons and interventional cardiologists | Successful implantation: 21/23 (91%) Note: 2 procedures in 1 patient Hemodynamic outcomes: 1) Change in valve area: 0.63 ± 0.18 → 1.45 ± 0.48 cm^2^ 2) Change in valve gradient: 34 ± 10 → 9 ± 2 mm Hg Clinical status outcomes: 1) Change in NYHA functional class: Not reported in a way that can be readily summarized 30-day survival: 20/22 (91%) | Complications: -Intraoperative death (n = 1) from electromechanical dissociation immediately after aortic valve implantation -Severe AR (n = 1) -Cardiac tamponade (n = 1) -Myocardial apical tear (n = 1) Valve dysfunction: Paravalvular AR in 13 patients (1+ in 9 patients, 2+ in 4 patients)
Rodés-Cabau, Houde, Perron, et al. 2008 50 | Country/countries: Canada Setting: NR Basic design: Case report Study objective(s): NR Duration of follow-up: 3 mo | No. of patients: 1 Age: 21 Sex: Female Medical/functional status: NR Surgical indication(s): Moderate pulmonary insufficiency. Patient was status post Ross procedure at age 10 for bicuspid aortic valve with severe aortic stenosis. Inclusion criteria: See under “Surgical indications,” above Exclusion criteria: NR | Valve name: Melody valve Size of catheter: NR Self-or balloon-expanding?: Balloon-expanding Implantation approach: Transfemoral antegrade Operator(s): NR | Successful implantation: 1/1 (100%) Hemodynamic outcomes: 1) Change in valve area: 0.65 → 0.96 cm^2^ 2) Change in peak valve gradient: 75 mm → 75 mm Hg 24 hr after the procedure Clinical status outcomes: Change in NYHA functional class: NR 30-day survival: 1/1 (100%) | Complications: None Valve dysfunction: None
Ruiz, Laborde, Condado, et al., 2008 51 | Country/countries: NR (authors from United States, France, and Venezuela) Setting: Cath lab Basic design: Case report Study objective(s): “To report the clinical, hemodynamic, and iconographic outcomes of the longest term survivor of the global CoreValve experience” Duration of follow-up: 3 yr | No. of patients: 1 Age: 58 Sex: Female Medical/functional status: NYHA IV Surgical indication(s): - Mixed aortic valve disease with severe AR and moderate AS - Patient was a candidate for surgical AVR, but she declined Inclusion criteria: NR Exclusion criteria: NR | Valve name: CoreValve Size of catheter: 1st generation 25 Fr delivery system Self- or balloon- expanding?: NR Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 1/2 (50%). First valve was deployed too proximal, necessitating deployment of a second valve (“valve in valve”) during the same 6-hr procedure. Hemodynamic outcomes: 1) Method of assessment: TEE 2) Change in valve area: NR 3) Change in valve gradient: NR 4) Other: NR Clinical status outcomes: 1) Change in NYHA functional class: IV → II 2) Other: Resolution of CHF symptoms 30-day survival: 1/1 (100%). 100% survival beyond 3 yr. | Complications: Severe AR from incorrect placement of first valve Valve dysfunction: - Leak: Trivial paravalvular - New moderate MR
Schofer, Schluter, Treede, et al., 2008 52 | Country/countries: Germany, United States Setting: NR Basic design: Case series Study objective(s): “To assess the feasibility and safety of retrograde transarterial implantation of a novel nonmetallic aortic valve prosthesis” Duration of follow-up: NR | No. of patients: 15 Age: NR Sex: NR Surgical indication(s): AS Inclusion criteria: NR Exclusion criteria: NR | Valve name: Direct Flow Medical aortic valve prosthesis Size of catheter: NR Self- or balloon- expanding?: NR Implantation approach: Retrograde Operator(s): NR | Successful implantation: 12/15 (80%) Hemodynamic outcomes: 1) Change in [underlined: median] valve area: 1.64 → 0.60 cm^2^ 2) Change in valve gradient: 54.0 → 14.0 mm Hg Clinical status outcomes: NR 30-day survival: 14/15 (93%) | Complications: - Death (n = 1) - Stroke (n = 1) Valve dysfunction: NR | Data abstracted from abstract only; trying to obtain copy of full text
Svensson, Dewey, Kapadia, et al., 2008 53 | Country/countries: United States Setting: “…mostly in hybrid fluoroscopy operating rooms. Early attempts to perform the procedure with mobile fluoroscopy units were abandoned.” Basic design: Case series Study objective(s): Evaluate “feasibility of… transcatheter approach” Duration of follow-up: Up to 341 days | No. of patients: 40 Age: Mean 83 (69 to 93) Sex: Female: 19 (48%) Male: 21 (52%) Medical/functional status: Mean STS score: 13.4% (4% to 47%) Logistic euroSCORE (mortality): 35.5% ± 15.3% Surgical indication(s): Critical AS Inclusion criteria: - Age > 70 - Valve area ≤ 0.6 cm^2^ - Society of Thoracic Surgeons score > 15% - Or deemed inoperable Exclusion criteria: NR | Valve name: Edwards Sapien Tanscatheter Heart Valve Size of catheter: NR Self- or balloon- expanding?: Balloon- expanding Implantation approach: Transapical Operator(s): NR | Successful implantation: 40 (100%) valves successfully delivered (35 [88%] successfully seated) Hemodynamic outcomes: 1) Change in valve area: 0.62 ± 0.13 → 1.61 ± 0.37 cm^2^ 2) Change in valve gradient: mean gradient 40 ± 9.8 → 7.7 ± 2.5 mm Hg 3) Other – AR: 1.4 →1.2 (NS) Clinical status outcomes: Change in NYHA functional class: 3.33 → 2.25 (p < 0.0001) 30-day survival: 33/40 (83%). 7 died within 30 days. An additional 2 died after 30 days. | Complications: - 3 deaths on day of operation - MI: 7 (18%) - Stroke: 2 (5%) - MACCE: 21 (53%) - Serious AE: 29 (73%) Valve dysfunction: - Leak: 0 - Migration: 1 (3%) - Need for re- intervention: 3 (8%) - Embolization: 3 (8%) - Severe AR: 1 (3%) - Leak at 30 days: 0 = 19% 1+ = 46% 2+ = 31% 3+ = 4% 4+ = 0% | Author states that “this new method may offer previously untreated patients or turned-down patients a new avenue of treatment provided procedural difficulties can be overcome.”
Tamburino, Capodanno, Mule, et al., 2009 54 | Country/countries: Italy Setting: NR Basic design: Prospective, nonrandomized study Study objective(s): To report acute and short-term outcomes of PAVR with the 18 Fr CoreValve Revalving System Duration of follow- up: Range: 1–13 months Mean: 4.9 ± 4 months | No. of patients: 30 Age: Mean: 82 ± 5 Range: 73–88 Sex: Female: 17 (57%) Male: 13 (43%) Medical/functional status: 10 pts NYHA I/II 20 pts NYHA III/IV Surgical indication(s): Severe AS Inclusion criteria: Native aortic valve stenosis with an aortic valve are < 1 cm^2^ (<0.6 cm^2^/m^2^) determined by echocardiography; aortic valve annulus diameter ≥ 20 mm and ≤ 27 mm; sinotubular junction ≤ 43 mm; diameter of iliac and femoral arteries ≥ 6 mm; contraindications to surgery because of concomitant comorbid conditions assessed and agreed to by both an independent cardiologist and a cardiovascular surgeon Exclusion criteria: Femoral, iliac, or aortic pathologies, aortic aneurysm, carotid or vertebral artery obstruction ≥ 70%, coagulopathies, myocardial infarction or cerebrovascular accident within the previous month, severe tricuspid or mitral valvular regurgitation, left ventricular or atrial thrombus, uncontrolled atrial fibrillation, sepsis or active endocarditis, hypersensitivity or contraindications to any medication used in the study | Valve name: Third- generation CoreValve Revalving System Size of catheter: 18 Fr Self- or balloon- expanding?: Self- expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 29/30 (97%) Hemodynamic outcomes: Method of assessment: Echocardiography C-cath Change in valve area: 0.61 ± 0.18 to 1.49 ± 0.39 cm^2^ (p < 0.001) Change in valve gradient: Peak: 85.6 ± 22.0 to 1.8 ± 4.0 mm Hg Clinical status outcomes: Change in NYHA functional class: 2.72 ± 0.59 pre-op to 1.31 ± 0.47 post-op (p < 0.001) Survival: At 30 days – 1 pt had died of hemorrhagic stroke and 1 had died as result of ischemic stroke which did not appear to be related to procedure | Complications: 1 pt required implantation of second CoreValve device due to unfavorable placement of first valve Major cardiovascular/ cerebrovascular events: Hemorrhagic stroke: 1 (3%) Valve dysfunction: Paravalvular leaks: 1+ in 12 pts 2+ in 2 pts
Ussia, Mule, and Tamburino, 2009 55 | Country/countries: Italy Setting: NR Basic design: Case report Study objective(s): “We report on a case o self-expandable biological valve prosthesis malpositioned high respect to the aortic valve annulus, resulting in severe aortic regurgitation treated with a second device implantation.” Duration of follow- up: 6 months | No. of patients: 1 Age: 84 Sex: Female Medical/functional status: NYHA III Surgical indication(s): Severe aortic valve stenosis and mitral regurgitation Inclusion criteria: NR Exclusion criteria: NR | Valve name: CoreValve Revalving System Size of catheter: 18 Fr Self- or balloon- expanding?: Self- expanding (though balloon was dilated for second implantation to ensure earlier problem would not reoccur) Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: First implantation failed due to malposition (“the valve slipped upward just above the aortic cusps”). Second prosthesis was implanted successfully. Hemodynamic outcomes: C-cath Echocardiography Change in valve area: 0.36 to NR Change in valve gradient: Peak: 50 to 5 mm Hg (intraoperatively) Mean: 30 to 10 mm Hg (at 6 mos f/u) Clinical status outcomes: Change in NYHA functional class: NYHA class I Survival: 1/1 (100%) at 60 days | Complications: Pseudo-aneurism of right femoral artery treated with surgical reduction Major cardiovascular/ cerebrovascular events: NR Valve dysfunction: Leak: 1+ paravalvular
Ussia, Barbanti, and Tamburino, 2009 56 | Country/countries: Italy Setting: NR Basic design: Case report Study objective(s): NR Duration of follow- up: 60 days | No. of patients: 1 Age: 85 Sex: Female Medical/functional status: NYHA class IV Surgical indication(s): Angina pectoris, severe dyspnea Inclusion criteria: NR Exclusion criteria: NR | Valve name: Third- generation CoreValve Revalving System Size of catheter: 18 Fr Self- or balloon- expanding?: Self- expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: Yes Hemodynamic outcomes: Method of assessment: TTE C-cath Change in valve area: NR Change in valve gradient: Peak: 45 to 15 mm Hg Clinical status outcomes: Change in NYHA functional class: NYHA class I (after discharge) Survival: 1/1 (100%) at 60 days | Complications of procedure: NR Major cardiovascular/ cerebrovascular events: NR Valve dysfunction: Leak: 2+ paravalvular leak
Walther, Falk, Kemfert, et al. 2008 57 | Country/countries: Germany, Austria, United States Setting: Hybrid operating theater Basic design: Case series Study objective(s): “To analyze the results of the initial 50 patients receiving transapical aortic valve implantation at a single center.” Duration of follow- up: Up to 18 mo | No. of patients: 50 Age: 82.4 ± 4.6 Sex: Female: 39 (78%) Male: 11 (22%) Medical/functional status: NYHA: 3.4 ± 0.5 Logistic euroSCORE (mortality): 27.6 ± 12.2% Surgical indication(s): Severe symptomatic AS and high perioperative risk Inclusion criteria: - Age > 75 - Surgical high risk as judged by a EuroSCORE of > 9 - Aortic annulus diameter < 24 mm - Symmetrically distributed calcification of the stenotic native aortic valve cusps Exclusion criteria: NR | Valve name: Edwards SAPIEN THV Size of catheter: 14 Fr introducer sheath Valve diameter: 23 mm (n = 13) 26 mm (n = 37) Self- or balloon- expanding?: NR Implantation approach: Transapical Operator(s): Cardiac surgeons and cardiologists | Successful implantation: 50/50 (100%) Hemodynamic outcomes: 1) Change in valve area: NR 2) Change in valve gradient: NR Clinical status outcomes: Change in NYHA functional class: NR 30-day survival: 46/50 (92%) 6-mo survival: 73.9% ± 6.2% 12-mo survival: 71.4% ± 6.5% | Complications: - Valve dislocation - Aortic root dissection - Coronary occlusion Valve dysfunction: NR | 30-patient overlap with Walther, Simon, Dewey, et al. 2007^58^ and Walther, Falk, Borger, et al., 2007^59^ (i.e., the same 30 patients are described in all 3 study reports)
Walther, Simon, Dewey, et al. 2007 58 and Walther, Falk, Borger, et al., 2007 59 | Country/countries: Germany, Austria, United States Setting: Routine operative theater Basic design: Multicenter case series Study objective(s): “To present the initial multicenter results of the first ethically approved clinical trial for transapical minimally invasive aortic valve implantation” Duration of follow-up: Mean 110 days (range, 1 to 255 days) | No. of patients: 59 By site: Leipzig (n = 30); Vienna (n = 24) Frankfurt (n = 3) Dallas (n = 2) Age: 81 ± 6 Sex: Female: 44 (75%) Male: 15 (25%) Medical/functional status: NYHA: 3.4 ± 0.5 Logistic euroSCORE risk score (mortality): 27 ± 14% euroSCORE: 11.2 ± 1.8 Surgical indication(s): Severe symptomatic AS Inclusion criteria: - Age > 75 - Surgical high risk as judged by a EuroSCORE of > 9 - Aortic annulus diameter < 24 mm - Symmetrically distributed calcification of the stenotic native aortic valve cusps Exclusion criteria: NR | Valve name: Edwards SAPIEN THV Size of catheter: 14 Fr soft sheath Self- or balloon- expanding?: Balloon- expanding Implantation approach: Transapical Operator(s): Cardiac surgeons and cardiologists | Successful implantation: 54 (92%) patients, with one successful conversion to conventional valve replacement Hemodynamic outcomes: 1) Change in valve area: NR 2) Change in valve gradient: mean gradient 43 ± 14 → 9 ± 6 mm Hg (95% CI: 7.3, 10,7) Clinical status outcomes: Change in NYHA functional class: NR 30-day survival: 1) 51/59 (86%) 2) 3 deaths in hospital from non-valvular causes | Complications: - Perioperative conversion to sternotomy (n = 4) - New pacemaker (n = 2) - Stroke (n = 2) - Pleural effusion (n = 18) - Supraventricular arrhythmia (n = 18) - Tracheostomy (n = 8) Aortic incompetence at time of hospital discharge (n = 40): Leak: - None: 14 (35%) - Trace/mild: 23 (58%) - Mod/severe: 3 (8%) | 30-patient overlap with Walther, Falk, Kemfert, et al. 2008^57^ (i.e., the same 30 patients are described in all 3 study reports)
Webb, Altwegg, Masson, et al., 2009 60 | Country/countries: Canada Setting: Cath lab Basic design: Case series Study objective(s): “We describe a new delivery system and next-generation balloon-expandable valve in a case series of 25 high-risk patients undergoing transarterial AVR.” Duration of follow- up: 30 days | No. of patients: 25 Age: Mean 85; range, 79–88 Sex: Female: 13 (52%) Male: 12 (48%) Medical/functional status: NYHA class I: 1 (4%) II: 2 (8%) III: 14 (56%) IV: 8 (32%) Surgical indication(s): AS Inclusion criteria: Symptomatic AS in whom the risk associated with open heart surgery was considered prohibitive by a team of cardiologists and cardiac surgeons. Exclusion criteria: Annulus diameter < 18 or > 26 mm or severe iliofemoral arterial disease, or if reasonable quality or duration of life was unlikely | Valve name: SAPIEN (n = 22) SAPIEN XT (n = 3) Size of catheter: 22 Fr or 24 Fr Self- or balloon- expanding?: Balloon Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: SAPIEN 22/22 (100%) SAPIEN XT 3/3 (100%) Hemodynamic outcomes: 1) Method of assessment: Echocardiography 2) Change in valve area: 0.59 ± 0.15 to 1.6 ± 0.27 cm^2^ 3) Change in valve gradient: 49.3 ± 17.9 to 10.6 ± 2.9 mm HG 4) Other: All patients had normal prosthetic valve function at 1-month f/u Clinical status outcomes: 1) Change in NYHA functional class: NR 2) 30-day survival: 25/25 (100%) | Complications: None reported Major cardiovascular/ cerebrovascular events: 2/25 (4%) with stroke or MI during 30-day f/u Valve dysfunction: 1 patient had more than mild valvular regurgitation
Webb, Pasupati, Humphries, et al., 2007 61 and Webb, Chandavim ol, Thompson, et al., 2006 62 and Clavel, Webb, Pibarot, et al., 2009 63 and Gutierrez M, Rodes-Cabau J, Bagur R, et al., 2009 64 | Country/countries: Canada Setting: Cath lab Basic design: Case series Study objective(s): “We report the early and late outcomes with this procedure in the initial 50 high-risk patients.” Duration of follow- up: Median 359 days | No. of patients: 50 Age: 82 ± 7 (62 to 94) Sex: Female: 20 (40%) Male: 30 (60%) Medical/functional status: NYHA class II: 5 (10%) NYHA class III: 32 (64%) NYHA class IV: 13 (26%) Logistic euroSCORE (mortality): 28% Surgical indication(s): Severe AS Inclusion criteria: Not candidates for surgery Exclusion criteria: NR | Valve name: Cribier Edwards Size of catheter: NR Self- or balloon- expanding?: Balloon- expanding Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 43/50 (86%) success Reasons for failure: - Inaccessible iliac access: 1 - Inability to cross aortic valve: 3 - Defective delivery catheter: 1 - Malpositioning: 2 Hemodynamic outcomes: 1) Change in valve area: 0.6 ± 0.2 → 1.7 ± cm^2^ 2) Change in valve gradient: Mean 46 ± 17 → 11 ± 5 mm Hg 3) Other: LVEF 53 ± 15% → 57 ± 13% MR decreased from median Grade 2 → 1 Clinical status outcomes: Change in NYHA functional class: 50% of patients improved ≥ 1 class at 30 days 30-day survival: 44/50 (88%) | Complications: - Death from aortic injury: 1 (2%) - Stroke: 2 (4%) - MI: 1 (2%) - Iliac artery perforation: 1(2%) - Ventricular fibrillation: 2 (4%) - Tamponade: 1 (2%) - Heart block: 2 (4%) Valve dysfunction: Leak: Moderate paravalvular insufficiency 3 (6%) AR Grade improved in 32%, was unchanged in 24%, and worsened in 44%
Wenaweser, Buellesfeld, Gerckens, et al., 2007 65 | Country/countries: Germany Setting: NR Basic design: Case report Study objective(s): NR Duration of follow-up: 12 mo | No. of patients: 1 Age: 80 Sex: Male Medical/functional status: NYHA class: IV Logistic euroSCORE (mortality): 35.6% Surgical indication(s): - Severe AR of a bioprosthesis - Prior surgical valve replacement - History of endocarditis - History of 2 prior thoracotomies - Refuses surgery Inclusion criteria: See “Surgical indications,” above Exclusion criteria: NR | Valve name: CoreValve ReValving System (2nd generation) Size of catheter: 21 Fr Self- or balloon- expanding?: NR Implantation approach: Transfemoral retrograde Operator(s): NR | Successful implantation: 1 (100%) Hemodynamic outcomes: 1) Change in valve area: NR 2) Change in valve gradient: NR 3) Other – cardiac output: 2.6 → 4.4 L/min Clinical status outcomes: Change in NYHA functional class: Class IV → Class I 30-day survival: 1 (100%). 100% survival at 1 yr as well. | Complications: None Valve dysfunction: None | Article discusses the first “Valve in Valve” procedure
Wendt, Eggebrecht, Kahlert, et al., 2009 66 | Country/countries: Germany Setting: Hybrid OR Basic design: Case report Study objective(s): “We report a successful transapical aortic valve implantation performed in a 96 y/o woman demonstrating the potential o the novel technique as an alternative treatment option in old and multimorbid patients at high risk for conventional AR.” Duration of follow-up: 30 days | No. of patients: 1 Age: 96 Sex: Female Medical/functional status: NYHA class III/IV Surgical indication(s): Dyspnea and recurrent syncope based on severe aortic valve stenosis Inclusion criteria: NR Exclusion criteria: NR | Valve name: Edwards SAPIEN Size of catheter: NR Self- or balloon- expanding?: Balloon- expanding Implantation approach: Transapical Operator(s): NR | Successful implantation: Yes Hemodynamic outcomes: Method of assessment: TTE C-cath Change in valve area: 0.4 to 1.7 cm^2^ at 30-day f/u Change in valve gradient: Mean: 61 to 6 mm Hg at 30 day f/u Clinical status outcomes: Change in NYHA functional class: NYHA class I at 30 days Survival: 1/1 at 30 days | Complications: Mild renal impairment Major cardiovascular/ cerebrovascular events: NR Valve dysfunction: Leak: “No signs of paravalvular leakage”
Wong, Boone, Thompson, et al., 2009 67 | Country/countries: Canada Setting: NR Basic design: Case report Study objective(s): NR Duration of follow-up: 13 months | No. of patients: 1 Age: 88 Sex: Male Medical/functional status: NR Surgical indication(s): Symptomatic severe AS Inclusion criteria: NR Exclusion criteria: NR | Valve name: Edwards SAPIEN Size of catheter: NR Self- or balloon- expanding?: Balloon- expanding Implantation approach: NR Operator(s): NR | Successful implantation: Suboptimal valve placement, but successful Hemodynamic outcomes: TTE Change in valve area: NR Change in valve gradient: NR Clinical status outcomes: Change in NYHA functional class: NR Survival: Alive at 11- month f/u | Complications: Moderate paravalvular AR treated with repeated balloon redilation without altering the valve position Major cardiovascular/ cerebrovascular events: None Valve dysfunction: Leak: Paravalvular | Pt presented 11 months post-op with fever and streptococcus in blood culture (from dental procedure without endocarditis prophylaxis) – treatment was complicated by renal failure, pneumonia, delirium, and dysphagia
Ye, Webb, Cheung, et al., 2009 68 | Country/countries: Canada Setting: Operating room Basic design: Case report Study objective(s): NR Duration of follow-up: 16 months | No. of patients: 1 Age: 85 Sex: Male Medical/functional status: NYHA III/IV Surgical indication(s): Severe aortic regurgitation, associated with pulmonary hypertension and preserved LV systolic function Inclusion criteria: NR Exclusion criteria: NR | Valve name: Edwards SAPIEN Size of catheter: NR Self- or balloon- expanding?: Balloon- expanding Implantation approach: Transapical Operator(s): NR | Successful implantation: This was a valve-in-valve implantation after earlier prosthesis was failing Hemodynamic outcomes: Echocardiography Fluoroscopy Change in valve area: NR Change in valve gradient: NR Change in NYHA functional class: Class I at 16 months Survival: Yes, at 16 months | Complications: None Major cardiovascular/ cerebrovascular events: None Valve dysfunction: None
Zierer, Wimmer- Greinecker, Martens, et al., 2008 69 | Country/countries: Germany Setting: Specially equipped angiography suite (hybrid operating room) Basic design: Case series Study objective(s): “To report our initial clinical experience in 26 consecutive patients who underwent antegrade placement of a catheter-deliverable aortic valve” Duration of follow-up: NR | No. of patients: 26 Age: 84 ± 7 Sex: Female: 20 (77%) Male: 6 (23%) Medical/functional status: NYHA class 3.5 ± 0.4 Surgical indication(s): AS Inclusion criteria: - Age ≥ 75 - Severe symptomatic AS - Aortic valve orifice ≤ 0.8 cm^2^ - High surgical risk (EuroSCORE predicted risk > 20%) - Aortic valve diameter ≤ 24 mm Exclusion criteria: - Aortic annulus diameter > 25 mm - Non-calcified AS - Subvalvular AS - Bicuspid aortic valve - Intracardiac thrombus - Endocarditis - Untreated symptomatic coronary artery disease - Recent ME - EF < 20% - Recent stroke - Hypertrophic obstructive cardiomyopathy | Valve name: Cribier- Edwards 23 mm (n = 11) 26 mm (n = 15) Size of catheter: 14 Fr soft sheath Self- or balloon- expanding?: Balloon- expanding Implantation approach: Transapical Operator(s): NR | Successful implantation: 25/26 (96%) Hemodynamic outcomes: 1) Method of assessment: TEE 2) Change in valve area: NR 3) Change in valve gradient: NR Clinical status outcomes: NR 30-day survival: 22/26 (85%) | Complications: - 2 (8%) conversion to open surgery - 2 (8%) left main stem obstruction - 3 (12%) severe hypotension - 1 (4%) intraoperative death from aortic root dissection - 1 (4%) death from right ventricle perforation - 1 (4%) aortic annulus rupture Valve dysfunction: Mild-moderate AI due to paravalvular leakages

## References to Appendix B

1 Kassai B, Gueyffier F, Cucherat M, et al. Comparison of bioprosthesis and mechanical valves, a meta-analysis of randomised clinical trials [erratum appears in Cardiovasc Surg 2001 Jun;9(3):304–306]. Cardiovasc Surg. 2000;8(6):477-483. [pmid: 10996104].
2 Kunadian B, Vijayalakshmi K, Thornley AR, et al. Meta-analysis of valve hemodynamics and left ventricular mass regression for stentless versus stented aortic valves. Ann Thorac Surg. 2007;84(1):73-78. [pmid: 17588387].
3 Lund O, Bland M. Risk-corrected impact of mechanical versus bioprosthetic valves on long-term mortality after aortic valve replacement. J Thorac Cardiovasc Surg. 2006;132(1):20-26. [pmid: 16798297].
4 Puvimanasinghe JPA, Takkenberg JJM, Edwards MB, et al. Comparison of outcomes after aortic valve replacement with a mechanical valve or a bioprosthesis using microsimulation. Heart. 2004;90(10):1172-1178. [pmid: 15367517].
5 Puvimanasinghe JPA, Takkenberg JJM, Eijkemans MJC, et al. Choice of a mechanical valve or a bioprosthesis for AVR: does CABG matter. Eur J Cardiothorac Surg. 2003;23(5):688-695. discussion 695. [pmid: 12754019].
6 Puvimanasinghe JPA, Takkenberg JJM, Eijkemans MJC, et al. Comparison of Carpentier-Edwards pericardial and supraannular bioprostheses in aortic valve replacement. Eur J Cardiothorac Surg. 2006;29(3):374-379. [pmid: 16386920].
7 Rizzoli G, Vendramin I, Nesseris G, et al. Biological or mechanical prostheses in tricuspid position? A meta-analysis of intra-institutional results. Ann Thorac Surg. 2004;77(5):1607-1614. [pmid: 15111151].
8 Al-Attar N, Raffoul R, Himbert D, et al. False aneurysm after transapical aortic valve implantation. J Thorac Cardiovasc Surg. 2009;137(1):e21-e22. [pmid: 19154869].
9 Asgar AW, Mullen MJ, Delahunty N, et al. Transcatheter aortic valve intervention through the axillary artery for the treatment of severe aortic stenosis. J Thorac Cardiovasc Surg. 2009;137(3):773-775. [pmid: 19258115].
10 Bauer F, Eltchaninoff H, Tron C, et al. Acute improvement in global and regional left ventricular systolic function after percutaneous heart valve implantation in patients with symptomatic aortic stenosis [erratum appears in Circulation 2005 Jan 25;111(3):378]. Circulation. 2004;110(11):1473-1476. [pmid: 15226213].
11 Bauernschmitt R, Schreiber C, Bleiziffer S, et al. Transcatheter aortic valve implantation through the ascending aorta: an alternative option for no-access patients. Heart Surgery Forum. 2009;12(1):E63-E64. [pmid: 19233771].
12 Berry C, Asgar A, Lamarche Y, et al. Novel therapeutic aspects of percutaneous aortic valve replacement with the 21F CoreValve Revalving System. Catheter Cardiovasc Interv. 2007;70(4):610-616. [pmid: 17894307].
13 Berry C, Cartier R, Bonan R. Fatal ischemic stroke related to nonpermissive peripheral artery access for percutaneous aortic valve replacement. Catheter Cardiovasc Interv. 2007;69(1):56-63. [pmid: 17154428].
14 Bleiziffer S, Ruge H, Mazzitelli D, et al. Valve implantation on the beating heart: catheter-assisted surgery for aortic stenosis. Dtsch Arztebl Int. 2009;106(14):235-241. [pmid: 19547639].
15 Bojara W, Mumme A, Gerckens U, et al. Implantation of the CoreValve self-expanding valve prosthesis via a subclavian artery approach: a case report. Clin Res Cardiol. 2009;98(3):201-204. [pmid: 19219393].
16 Bollati M, Moretti C, Omede P, et al. Percutaneous aortic valve replacement in two cases at high surgical risk: procedural details and implications for patient selection. Minerva Cardioangiol. 2009;57(1):131-136. [pmid: 19202524].
17 Buellesfeld L, Gerckens U, Grube E. Percutaneous implantation of the first repositionable aortic valve prosthesis in a patient with severe aortic stenosis. Catheter Cardiovasc Interv. 2008;71(5):579-584. [pmid: 18360844].
18 Chandavimol M, McClure SJ, Carere RG, et al. Percutaneous aortic valve implantation: a case report. Can J Cardiol. 2006;22(13):1159-1161. [pmid: 17102835].
19 Cheung A, Webb JG, Wong DR, et al. Transapical transcatheter mitral valve-in-valve implantation in a human. Ann Thorac Surg. 2009;87(3):e18-e20. [pmid: 19231366].
20 Chiam PTL, Koh TH, Chao VTT, et al. Percutaneous transcatheter aortic valve replacement: first transfemoral implant in Asia. Singapore Med J. 2009;50(5):534-537. [pmid: 19495528].
21 Clavel MA, Dumont E, Pibarot P, et al. Severe valvular regurgitation and late prosthesis embolization after percutaneous aortic valve implantation. Ann Thorac Surg. 2009;87(2):618-621. [pmid: 19161796].
22 Cribier A, Eltchaninoff H, Tron C, et al. Early experience with percutaneous transcatheter implantation of heart valve prosthesis for the treatment of end-stage inoperable patients with calcific aortic stenosis. J Am Coll Cardiol. 2004;43(4):698-703. [pmid: 14975485].
23 Eltchaninoff H, Tron C, Cribier A. Percutaneous implantation of aortic valve prosthesis in patients with calcific aortic stenosis: technical aspects. J Intervent Cardiol. 2003;16(6):515-521. [pmid: 14632949].
24 Cribier A, Eltchaninoff H, Bash A, et al. Percutaneous transcatheter implantation of an aortic valve prosthesis for calcific aortic stenosis: first human case description. Circulation. 2002;106(24):3006-3008. [pmid: 12473543].
25 Cribier A, Eltchaninoff H, Tron C, et al. Treatment of calcific aortic stenosis with the percutaneous heart valve: mid-term follow-up from the initial feasibility studies: the French experience. J Am Coll Cardiol. 2006;47(6):1214-1223. [pmid: 16545654].
26 Dumonteil N, Marcheix B, Berthoumieu P, et al. Transfemoral aortic valve implantation with pre-existent mechanical mitral prosthesis. Evidence of feasibility. JACC: Cardiovascular Interventions. 2009;2(9):897-898. [pmid: 19778782].
27 Dvir D, Assali A, Vaknin H, et al. Percutaneous aortic valve implantation: early clinical experience and future perspectives. Isr Med Assoc J. 2009;11(4):244-249. [pmid: 19603600].
28 Falk V, Schwammenthal EE, Kempfert J, et al. New anatomically oriented transapical aortic valve implantation. Ann Thorac Surg. 2009;87(3):925-926. [pmid: 19231421].
29 Geist V, Sherif MA, Khattab AA. Successful percutaneous coronary intervention after implantation of a CoreValve percutaneous aortic valve. Catheter Cardiovasc Interv. 2009;73(1):61-67. [pmid: 19089940].
30 Grube E, Buellesfeld L, Mueller R, et al. Progress and current status of percutaneous aortic valve replacement: results of three device generations of the CoreValve Revalving system. Circulation: Cardiovascular Interventions. 2008;1:167-175. [pmid: 20031675].
31 Grube E, Laborde JC, Gerckens U, et al. Percutaneous implantation of the CoreValve self-expanding valve prosthesis in high-risk patients with aortic valve disease: the Siegburg first-in-man study. Circulation. 2006;114(15):1616-1624. [pmid: 17015786].
32 Grube E, Schuler G, Buellesfeld L, et al. Percutaneous aortic valve replacement for severe aortic stenosis in high-risk patients using the second- and current third-generation self-expanding CoreValve prosthesis: device success and 30-day clinical outcome. J Am Coll Cardiol. 2007;50(1):69-76. [pmid: 17601548].
33 Grube E, Laborde JC, Zickmann B, et al. First report on a human percutaneous transluminal implantation of a self-expanding valve prosthesis for interventional treatment of aortic valve stenosis. Catheter Cardiovasc Interv. 2005;66(4):465-469. [pmid: 16208696].
34 Hanzel GS, Harrity PJ, Schreiber TL, et al. Retrograde percutaneous aortic valve implantation for critical aortic stenosis. Catheter Cardiovasc Interv. 2005;64(3):322-326. [pmid: 15736245].
35 Himbert D, Descoutures F, Al-Attar N, et al. Results of transfemoral or transapical aortic valve implantation following a uniform assessment in high-risk patients with aortic stenosis. J Am Coll Cardiol. 2009;54(4):303-311. [pmid: 19608027].
36 Kapadia SR, Svensson L, Tuzcu EM. Successful percutaneous management of left main trunk occlusion during percutaneous aortic valve replacement. Catheter Cardiovasc Interv. 2009;73(7):966-972. [pmid: 19455695].
37 Klaaborg KE, Egeblad H, Jakobsen CJ, et al. Transapical transcatheter treatment of a stenosed aortic valve bioprosthesis using the Edwards SAPIEN Transcatheter Heart Valve. Ann Thorac Surg. 2009;87(6):1943-1946. [pmid: 19463633].
38 Kolettis TN, Spargias K, Stavridis GT. Combined transapical aortic valve implantation with coronary artery bypass grafting in a young patient with porcelain aorta. Hellenic J Cardiol. 2009;50(1):79-82. [pmid: 19196626].
39 Lamarche Y, Cartier R, Denault AY, et al. Implantation of the CoreValve percutaneous aortic valve. Ann Thorac Surg. 2007;83(1):284-287. [pmid: 17184681].
40 Lange R, Schreiber C, Gotz W, et al. First successful transapical aortic valve implantation with the Corevalve Revalving system: a case report. Heart Surgery Forum. 2007;10(6):E478-E479. [pmid: 18187382].
41 Lichtenstein SV, Cheung A, Ye J, et al. Transapical transcatheter aortic valve implantation in humans: initial clinical experience. Circulation. 2006;114(6):591-596. [pmid: 16880325].
42 Ye J, Cheung A, Lichtenstein SV, et al. Six-month outcome of transapical transcatheter aortic valve implantation in the initial seven patients. Eur J Cardiothorac Surg. 2007;31(1):16-21. [pmid: 17126558].
43 Marcheix B, Lamarche Y, Berry C, et al. Surgical aspects of endovascular retrograde implantation of the aortic CoreValve bioprosthesis in high-risk older patients with severe symptomatic aortic stenosis. J Thorac Cardiovasc Surg. 2007;134(5):1150-1156. [pmid: 17976442].
44 Moreno R, Dobarro D, Lopez de Sa E, et al. Cause of complete atrioventricular block after percutaneous aortic valve implantation: insights from a necropsy study. Circulation. 2009;120(5):e29-e30. [pmid: 19652115].
45 Ng AC, van der Kley F, Delgado V, et al. Percutaneous valve-in-valve procedure for severe paravalvular regurgitation in aortic bioprosthesis. JACC Cardiovasc Imaging. 2009;2(4):522-523. [pmid: 19580737].
46 Paniagua D, Condado JA, Besso J, et al. First human case of retrograde transcatheter implantation of an aortic valve prosthesis. Tex Heart Inst J. 2005;32(3):393-398. [pmid: 16392228].
47 Piazza N, Schultz C, de Jaegere PP, et al. Implantation of two self-expanding aortic bioprosthetic valves during the same procedure-Insights into valve-in-valve implantation (“Russian doll concept”). Catheter Cardiovasc Interv. 2009;73(4):530-539. [pmid: 19133687].
48 Piazza N, Serruys PW, de Jaegere P. Feasibility of complex coronary intervention in combination with percutaneous aortic valve implantation in patients with aortic stenosis using percutaneous left ventricular assist device (TandemHeart). Catheter Cardiovasc Interv. 2009;73(2):161-166. [pmid: 19160444].
49 Rodés-Cabau J, Dumont E, De LaRochellière R, et al. Feasibility and initial results of percutaneous aortic valve implantation including selection of the transfemoral or transapical approach in patients with severe aortic stenosis. Am J Cardiol. 2008;102(9):1240-1246. [pmid: 18940300].
50 Rodés-Cabau J, Houde C, Perron J, et al. Delayed improvement in valve hemodynamic performance after percutaneous pulmonary valve implantation. Ann Thorac Surg. 2008;85(5):1787-1788. [pmid: 18442588].
51 Ruiz CE, Laborde JC, Condado JF, et al. First percutaneous transcatheter aortic valve-in-valve implant with three year follow-up. Catheter Cardiovasc Interv. 2008;72(2):143-148. [pmid: 18655115].
52 Schofer J, Schluter M, Treede H, et al. Retrograde transarterial implantation of a nonmetallic aortic valve prosthesis in high-surgical-risk patients with severe aortic stenosis: a first-in-man feasibility and safety study. Circulation: Cardiovascular Interventions. 2008;1:126-133. [pmid: 20031667].
53 Svensson LG, Dewey T, Kapadia S, et al. United States feasibility study of transcatheter insertion of a stented aortic valve by the left ventricular apex. Ann Thorac Surg. 2008;86(1):46-54. discussion 54–55. [pmid: 18573397].
54 Tamburino C, Capodanno D, Mule M, et al. Procedural success and 30-day clinical outcomes after percutaneous aortic valve replacement using current third-generation self-expanding CoreValve prosthesis. J Invasive Cardiol. 2009;21(3):93-98. [pmid: 19258637].
55 Ussia GP, Mule M, Tamburino C. The valve-in-valve technique: transcatheter treatment of aortic bioprothesis malposition. Catheter Cardiovasc Interv. 2009;73(5):713-716. [pmid: 19180656].
56 Ussia GP, Barbanti M, Tamburino C. Treatment of severe regurgitation of stentless aortic valve prosthesis with a self-expandable biological valve. J Invasive Cardiol. 2009;21(3):E51-E54. [pmid: 19258652].
57 Walther T, Falk V, Kempfert J, et al. Transapical minimally invasive aortic valve implantation; the initial 50 patients. Eur J Cardiothorac Surg. 2008;33(6):983-988. [pmid: 18294859].
58 Walther T, Simon P, Dewey T, et al. Transapical minimally invasive aortic valve implantation: multicenter experience. Circulation. 2007;116(11 Suppl):I240-I245. [pmid: 17846311].
59 Walther T, Falk V, Borger MA, et al. Minimally invasive transapical beating heart aortic valve implantation--proof of concept. Eur J Cardiothorac Surg. 2007;31(1):9-15. [pmid: 17097302].
60 Webb JG, Altwegg L, Masson JB, et al. A new transcatheter aortic valve and percutaneous valve delivery system. J Am Coll Cardiol. 2009;53(20):1855-1858. [pmid: 19442884].
61 Webb JG, Pasupati S, Humphries K, et al. Percutaneous transarterial aortic valve replacement in selected high-risk patients with aortic stenosis. Circulation. 2007;116(7):755-763. [pmid: 17646579].
62 Webb JG, Chandavimol M, Thompson CR, et al. Percutaneous aortic valve implantation retrograde from the femoral artery. Circulation. 2006;113(6):842-850. [pmid: 16461813].
63 Clavel MA, Webb JG, Pibarot P, et al. Comparison of the hemodynamic performance of percutaneous and surgical bioprostheses for the treatment of severe aortic stenosis. J Am Coll Cardiol. 2009;53(20):1883-1891. [pmid: 19442889].
64 Gutierrez M, Rodes-Cabau J, Bagur R, et al. Electrocardiographic changes and clinical outcomes after transapical aortic valve implantation. Am Heart J. 2009;158(2):302-308. [pmid: 19619709].
65 Wenaweser P, Buellesfeld L, Gerckens U, et al. Percutaneous aortic valve replacement for severe aortic regurgitation in degenerated bioprosthesis: the first valve in valve procedure using the Corevalve Revalving system. Catheter Cardiovasc Interv. 2007;70(5):760-764. [pmid: 17932876].
66 Wendt D, Eggebrecht H, Kahlert P, et al. Successful transapical aortic valve implantation four weeks before 97th birthday. Interactive Cardiovascular & Thoracic Surgery. 2009;8(6):684-686. [pmid: 19286680].
67 Wong DR, Boone RH, Thompson CR, et al. Mitral valve injury late after transcatheter aortic valve implantation. J Thorac Cardiovasc Surg. 2009;137(6):1547-1549. [pmid: 19464478].
68 Ye J, Webb JG, Cheung A, et al. Transcatheter valve-in-valve aortic valve implantation: 16-month follow-up. Ann Thorac Surg. 2009;88(4):1322-1324. [pmid: 19766829].
69 Zierer A, Wimmer-Greinecker G, Martens S, et al. The transapical approach for aortic valve implantation. J Thorac Cardiovasc Surg. 2008;136(4):948-953. [pmid: 18954635].