# Exact Search Strategies

PubMed^®^ Search Strategy Used to Identify Systematic Reviews of Conventional Heart Valves (Question 2) Date of search: October 17, 2008

#1 | Heart Valve Prosthesis (29083)
#2 | Heart Valve Prosthesis Implantation (7798)
#3 | (Aortic Valve/surgery OR Aortic Valve/transplantation) (8179)
#4 | (Mitral Valve/surgery OR Mitral Valve/transplantation) (8271)
#5 | #1 OR #2 OR #3 OR #4 (34134)
#6 | #5 AND systematic[sb] (169)
#7 | Cochrane database syst Rev (5467)
#8 | Search [tw] (5467)
#9 | Meta-analysis [pt] (18848)
#10 | Systematic review [tw] (13902)
#11 | #7 OR #8 OR #9 OR #10 (121097)
#12 | #5 AND #11 (150)
#13 | #6 OR #12 (266)

PubMed^®^ Search Strategy Used to Identify Randomized Controlled Trials of Conventional Heart Valves (Question 2) Date of search: October 17, 2008

#1 | Heart Valve Prosthesis (29083)
#2 | Heart Valve Prosthesis Implantation (7798)
#3 | (Aortic Valve/surgery OR Aortic Valve/transplantation) (8179)
#4 | (Mitral Valve/surgery OR Mitral Valve/transplantation) (8271)
#5 | #1 OR #2 OR #3 OR #4 (34134)
#6 | randomized controlled trial[Publication Type] (257078)
#7 | (randomized[Title/Abstract] AND controlled[Title/Abstract] AND trial[Title/Abstract]) (36383)
#8 | #6 OR #7 (266338)
#9 | #5 AND #8 (483)
#10 | Limit to English and Human (416)

PubMed^®^ Search Strategy Used to Identify Observational Studies of Conventional Heart Valves (Question 2) Date of search: December 13, 2008

#1 | Heart Valve Prosthesis [Majr] (16659)
#2 | Heart Valve Prosthesis Implantation [Majr] (3989)
#3 | (Aortic Valve/surgery [Majr] OR Aortic Valve/transplantation [Majr]) (4604)
#4 | (Mitral Valve/surgery [Majr] OR Mitral Valve/transplantation [Majr]) (4555)
#5 | #1 OR #2 OR #3 OR #4 (23965)
#6 | Longitudinal OR cohort studies OR (relative risk OR (relative AND risk)) OR follow up studies (1615952)
#7 | #5 AND #6 (7319)
#8 | (Randomized[Title/Abstract] AND controlled [Title/Abstract]) OR randomized controlled trial[pt] (285005)
#9 | #7 NOT #8 (7087)
#10 | #9 Limits: Review (432)
#11 | #9 NOT #10 (6655)
#12 | #11 Limits: English, Humans, Adult: 19–44, Middle Aged+ Aged 45+ years, added to PubMed in the last 5 years (1157)

PubMed^®^ Search Strategy Used to Identify Studies of Percutaneous Heart Valves (Questions 3–4) Date of search: October 15, 2009

#1 | Percutaneous OR transapical OR transcatheter OR CoreValve OR Edwards OR Sapien (120603)
#2 | ((“Heart Valve Prosthesis”[Majr] OR “Heart Valve Prosthesis Implantation”[Majr]) OR (“Aortic Valve/surgery”[Majr] OR “Aortic Valve/transplantation”[Majr])) OR (“Mitral Valve/surgery”[Majr] OR “Mitral Valve/transplantation”[Majr] OR (“Pulmonic Valve/surgery”[Majr] OR “Pulmonic Valve/transplantation”[Majr] OR “Pulmonary Valve/surgery”[Majr] OR “PulmonaryValve/transplantation”[Majr]) (25756)
#3 | #1 AND #2 Limits: Humans, Clinical Trial, Case Reports (616)

EMBASE^®^ Search Strategy Used to Identify Studies of Percutaneous Heart Valves (Questions 3–4) Date of search: October 15, 2009

#1 | Heart Valve Prosthesis/de (18,068)
#2 | Aorta Valve/de or mitral valve/de or pulmonary valve/de (23,587)
#3 | #1 or #2 (35,879)
#4 | (Percutaneous or transapical or transcatheter or CoreValve or Edwards or Sapien) (158,669)
#5 | #3 and #4 (2,299)
#6 | clinical trial/exp or case report/de (2,419,486)
#7 | #5 and #6 and [embase]/lim (341)