# Acronyms and Abbreviations

ACC: American College of Cardiology
AHA: American Heart Association
AHRQ: Agency for Healthcare Research and Quality
AVR: Aortic valve replacement
CABG: Coronary artery bypass graft
CI: Confidence interval
EOA: Effective orifice area
EPC: Evidence-based Practice Center
FDA: U.S. Food and Drug Administration
LV: Left ventricular
OR: Odds ratio
PARTNER: Placement of AoRTic TraNscathetER trial
PHV: Percutaneous heart valve
QUOROM: Quality Of Reporting Of Meta-analyses
RCT: Randomized controlled trial
RR: Relative risk
SRC: Scientific Resource Center
WMD: Weighted mean difference