# Summary and Implications

Here we first present a summary of the key findings, and then we discuss the strengths and limitations of this report, factors limiting the impact and diffusion of public reporting sites, and the implications for research and policy.

## Key Findings

We highlighted the key findings from this report in Box 5. With regards to GQ1, which asks “what measures of costs about health care providers have been publicly reported?”, we reviewed 59 publicly available Web sites that met the inclusion and exclusion criteria. State health departments and state hospital associations hosted about three-quarters of the Web sites. Independent organizations hosted the remaining one-quarter. All of the Web sites reported information on inpatient services and about half of the Web sites reported information on both inpatient and outpatient services. Three Web sites specifically reported on nursing home costs. Very few Web sites reported information on emergency room or urgent care services. Most Web sites reported cost measures as “average charges.” Other reported cost measures included average costs, median charges, median Medicare payments, and a specified range of charges. Only one Web site explicitly provided information on patient's out-of-pocket expenses, and only one Web site differentiated between costs for insured and uninsured individuals. Nearly all of the reviewed Web sites used dollar amounts to report the cost measures, except one, which used representative symbols. The levels of comparison available to patients varied across Web sites, but the majority of Web sites enabled comparisons between hospital facilities. About one-quarter of the Web sites allowed cost comparisons across selected counties or regions within a state. Many Web sites compared costs to state or national benchmarks.

Box 5 Summary of key findings

GQ1: What measures of costs about health care providers have been publicly reported?
- We identified publicly available Web sites owned by state health departments, state hospital associations, and independent organizations.
- The Web sites reported data on inpatient, outpatient, and emergency room or urgent care services. Some only reported data from nursing homes.
- The Web sites reported costs as average charges, average costs, median charges, median Medicare payments, or a specified range of charges. One Web site reported out-of-pocket expenses.
- Web sites made comparisons between hospital facilities, across counties or regions, and to state or national benchmarks.

GQ2: Are the cost measures reported in a consumer-centered way?
- We developed the PRICE taxonomy of consumer centeredness focusing on five domains with three criteria each.
- When assessing the 15 criteria of the PRICE taxonomy, 8.3 was the average number of criteria met by the Web sites, with a median of 8 criteria met.
- The Web sites met the “ease of use” and “real comparisons” criteria most often, and the “information on value” and “connect to care” criteria the least.

With regards to GQ2 (Are the cost measures reported in a consumer-centered way?) we developed the PRICE taxonomy. This taxonomy uses five domains to assess consumer centeredness, including price transparency, real comparisons, information on value, connect to care, and ease of use. We rated Web sites using three criteria within each of these five domains, resulting in a maximum score of 15 points per Web site. The mean and median aggregate scores on the PRICE taxonomy were 8.3 and 8.0, respectively, with a range from 4 to 11. About 75 percent of the Web sites met at least half of the criteria detailed in the taxonomy. On average, the Web sites scored highest on the ease of use and real comparisons domains, while scores were lowest for information on value and connect to care. Nearly 80 percent of Web sites scored 2 out of 3 on the price transparency domain, and about 40 percent of the Web sites scored 3 out of 3 on the real comparisons domain. Weaknesses included a lack of information on out-of-pocket expenses and an absence of indicators of high-value providers. Strengths included clear descriptions of costs, definitions of terms when required, simple and understandable displays, and customizable searches on shoppable conditions.

### Strengths and Limitations

The literature on the public reporting of cost measures is not as well developed as that for the public reporting of quality indicators. This report is a comprehensive review of this emerging field, and it has both strengths and limitations (Table 6).

Table 6 Strength and limitations of this report

Strengths: | Limitations:
✓ We developed and implemented a novel taxonomy (PRICE) to rate the consumer centeredness of the Web sites.; ✓ We attempted to define measures of costs.; ✓ This is the most comprehensive list of Web sites that publicly report data on health care costs. The list covers a wide range of Web sites, including those hosted by state hospital associations, state departments of health, and independent organizations.; ✓ Although this was an environmental scan, we used a rigorous, systematic approach to search for Web sites and extract data. A double review of Web sites and data abstraction ensured the reliability of the method.; ✓ Our multidisciplinary research team provided a wide range of points of view and approaches to the study.; ✓ We identified gaps in the literature regarding the assessment/review of semipublic Web sites that report costs.; ✓ We engaged Key Informants who helped guide the methods of this report and determine what to look for in the data. | ✓ The PRICE taxonomy was not previously validated. We sought to compare our taxonomy to other available grading systems, but identified only one.; ✓ To find the Web sites in the list for this report, we used a review methodology including a targeted (rather than systematic) literature review, so there may be Web sites we missed.; ✓ We did not include any Web sites from individual providers or individual hospitals.; ✓ There was initial conceptual ambiguity in terms of abstracting the cost measures, and some flexibility was necessary in applying a data abstraction protocol.; ✓ We did not have access to enough semipublic Web sites to capture the current status of their consumer centeredness.; ✓ There was a lack of consumer representation and engagement in developing the review.; ✓ There is a lack of data on the effectiveness of publicly reporting cost measures.

The taxonomy we developed to assess the consumer centeredness of these Web sites was a notable strength of this project. This novel tool may prove useful in future research, although we recognize that it has not yet been validated. In addition, this taxonomy may be valuable for assessing new Web sites that publicly report cost data and could also serve as a guide to those entities creating these types of Web sites. We opted to equally weight the criteria in the taxonomy, as we had no a priori reason to more heavily value some criteria than others. In future work, we might find that some criteria are indeed stronger contributors to consumer centeredness and require greater weighting. Another strength of this report is the characterization of the diverse measures of cost reported by public reporting Web sites.

This study is notably limited by the lack of consumer engagement or representation. Our Key Informants have a great deal of knowledge and experience with consumer perspectives and helped us identify relevant articles and public reporting Web sites. However, as we did not engage consumers directly, we were unable to collect feedback from actual consumer's experiences with public reporting Web sites to refine our definition of consumer centeredness.

We excluded semipublic Web sites from our review, because they are only accessible to certain patient populations (such as consumers who have a specific health insurance plan) and they sometimes charge user fees. We did not have full access to these Web sites, and therefore, were unable to systematically assess whether they were consumer centered. We were, however, able to conduct a cursory review of five semipublic Web sites. We outlined the characteristics of those Web sites in Appendix D. There is an obvious gap in the current literature (including grey literature) detailing the content of semipublic Web sites and their consumer centeredness.

## Factors Limiting Impact and Diffusion

The impact and broad diffusion of publicly reporting data on costs is limited by several factors. First, the majority of Web sites reported their cost measures as charges, which are not relevant to many consumers, as health plans typically negotiate lower rates. The consumer centeredness of Web sites that do not report out-of-pocket costs is suspect. Web sites that do not directly report out-of-pocket costs are arguably less useful to consumers. Second, many of the cost measures are difficult for consumers to understand, as definitions and data sources vary across these Web sites. Standardizing cost measures and terms, and providing guidance to Web site developers as to what cost measures are most relevant to consumers may improve the impact and diffusion of public reporting of costs. Third, while some Web sites have an easy-to-follow interface, many other are hard to navigate, which limits their impact. For example, some Web sites do not easily allow consumers to choose relevant geographic locations, categories of service (inpatient, outpatient, emergency), conditions, or procedures. Fourth, Web sites that do not provide both cost and quality data can limit a consumer's ability to see how the two measures interrelate (i.e., how to get the most value for your money).

While mandates that require public reporting of costs will likely increase the availability of cost data, the impact and diffusion of this data are limited by a lack of awareness among consumers. Furthermore, mandates do not necessarily guarantee that Web sites report cost data that are relevant to consumers. This is likely because we don't have enough research on public reporting of costs to help guide the development and implementation of these mandates.

In addition to the need for more research on the impact and diffusion of public reporting of costs, Web sites should provide a place for consumers to provide feedback on the usefulness of the data and the Web site. Creating this type of forum where consumers can communicate their needs and suggest how the Web site can best meet those needs would significantly improve public reporting practices. Consumers would likely continue to visit the Web site if the developers adjusted their data and functionality according to consumer feedback and needs. There may be other ways to collect this information as well, such as consumer focus groups or Web site analytics.

Finally, consumers need to be informed about the availability and relevance of cost and quality data that compare different health care providers.24 While consumers may be aware of the variation in the quality of health care providers, they may not be aware of the variation in costs. To improve the impact and diffusion of public reporting of costs, we need public awareness programs to inform consumers that variations in cost exist, and that these variations have a large impact on health care and the health care system as a whole.

## Implications for Research and Policy

The public reporting of health care cost data is intended to help consumers better understand the variations that exist in these costs.24 It may also produce market forces that narrow the range of prices, stimulate price competition, and lower costs by encouraging cost-conscious shopping.5 These possible effects depend on many factors and may work via mechanisms other than consumer empowerment.35 Third-party vendors that deliver semipublic cost information to consumers (see Appendix D) may be more consumer centered as they are able to report on out-of-pocket expenses that would be anticipated based on an individual's insurance type. This being said, we would expect that any public reporting of the costs of services has some utility to consumers, even if it just makes them more cost-conscious.24

One risk, however, is that consumers use these data as a proxy for quality. As indicated by a number of experimental studies17, consumers tend to equate higher costs with higher quality services or providers, or conversely, that lower costs means poorer quality. These studies indicate that providing quality information along with cost information encourages consumers to choose a combination of cost and quality that yields higher value. This field needs more research that examines how publicly reported cost data (with and without quality data) helps consumers to choose health care providers. Similarly, studies are needed that examine the best way for consumers to provide feedback to Web site developers regarding content and ease-of-use.

Through our literature review and Key Informant interviews, we identified a number of research gaps related to the public reporting of health care cost information. There are little data on the expense of providing consumers personalized cost information on a large scale, specifically the expense associated with developing interfaces, providing services, ensuring accuracy, and guaranteeing privacy. Also, as the majority of public health care cost reporting is online, few if any studies have examined how the digital divide in the United States affects a disadvantaged or older consumer's access to health care cost information, and whether this impacts their ability to obtain high-value care.

We cannot know with certainty why hospitals do not report more explicitly on actual costs of care; it may because their accounting systems do not permit this to happen easily or because it is not in their best interests. Greater attention to why hospitals still use charge masters as references for the costs of health care resources or services might move hospitals away from the use of these data, which are largely uninformative to patients. Efforts towards a continuous data collection process for patient payments for services would yield a database that represents what patients actually pay for health care. This would be truly useful data to consumers.

Future research should look at the public reporting of cost data as an intervention, and measure the effect of these data on patient outcomes and costs. Health services researchers could examine trends over time as more publicly reported cost data become available to consumers and as the quality and consumer centeredness of the data improve. Researchers will need to find ways to overcome challenges associated with measuring the impact of public reporting on consumers. Further research that develops metrics for evaluating consumer centeredness may be beneficial in improving current practices. A better understanding of which components of consumer centeredness are most important will better inform methods for constructing these metrics. Each domain, and subsequent criteria within each domain, is equally weighted in this report. Empirical studies to determine the value of each of these components are necessary as we move forward, as are evaluations of these metrics that determine their reliability and validity.