# Results

## GQ1 What Measures of Costs About Health Care Providers Have Been Publicly Reported?

Several articles describe Web sites that publicly report health data. Kullgren et al. describes 62 Web sites reporting State-based health care prices.21 This study reports that most Web sites listed prices related to inpatient care for medical conditions (73 percent) and surgeries (71 percent), but did not regularly list prices associated with outpatient services. Most Web sites listed billed charges (81 percent) rather than costs, whereas a few Web sites estimated costs based on a specific health plan (8 percent). Sinaiko et al. found that information on total and out-of-pocket costs was available in some markets.5 Information on public reporting in states that have well-established reporting mechanisms (like New Hampshire) is prevalent in the literature.

We identified 372 Web sites that compared providers within a geographic area (using 5 sources) (Box 4). During the first phase of review, we triaged 135 of these Web sites for further review. During the second phase of review, we selected 59 of these Web sites for data abstraction and synthesis (Figure 1). Appendix B details all the Web sites that we reviewed.

Box 4 Five sources used in the environmental scan

O'Neil et al., 2010^22^ | This report by Mathematica Policy Research focused on the public reporting of community programs, health plans, hospitals, or physicians at the local, regional, state, and national levels. It provided the National Quality Forum with an assessment of public reporting programs in order to facilitate decisionmaking regarding public reporting.
Robert Wood Johnson Foundation, 2013^23^ | This is a master list of public reporting Web sites that serves as a directory of Web sites to help consumers find reliable information on health care costs, both locally and nationally. Additionally, we reviewed Web sites that had been excluded by the authors of the RWJF directory (i.e., Web sites that contained old data or that were expected to have information on quality only), as we thought that these Web sites might have been updated since their initial review.
Kullgren et al., 2013^21^ | This study described 62 state health care price Web sites and examined ways to improve the utility of publicly reported health care information. It used a systematic Internet search to identify Web sites.
Yegian et al., 2013^24^ | This study included a targeted literature review, Key Informant interviews, and a review of selected online cost and quality reporting efforts. It identified the lack of out-of-pocket expense data and quality data (both of which facilitate informed decisionmaking) as potential shortcomings.
Informed Patient Institute (IPI) – Nonprofit organization, 2014^25^ | The IPI is an independent nonprofit organization that provides online information about health care quality and patient safety for consumers. IPI does not rate individual health facilities or professionals. Instead, IPI assesses the usefulness of online “report card” sites about doctors, hospitals, and nursing homes. We included a list of links, from the IPI database, to over 30 report cards with cost information.

Figure 1 Review of public-reporting Web sites

Figure 1: The figure shows the review of websites via a vertical search flow diagram. The first box shows the sources from which websites were identified, The Robert Wood Johnson Foundation, Mathematica report, seminal journal articles, Informed Patient Institute and Key Informants, and the number of websites from each source. The next box has total retrieved websites. Then there is a box to the right has the number of duplicate websites, then first-phase screening review, then a box to the right with excluded websites and then another box to right with reasons for exclusion. Then below there is second-phase screening review, with a box to the right with excluded articles and another box to the right with reasons for exclusion at this level. Finally, there is a box with the final number of the included websites.

Data extracted from the final set of 59 Web sites provided insight into the range of information available to consumers (Appendix C). State health departments or state hospital associations owned approximately three-quarters of Web sites. Independent organizations such as Aligning Forces Humboldt, Clear Health Costs, and The Commonwealth Fund owned the remaining quarter of the Web sites. All 59 Web sites provided cost data on inpatient services. Of these, 31 provided information on both inpatient and outpatient services, three only provided daily rates for private or semi-private rooms in nursing homes, and five offered information on emergency room visits or urgent care needs.

Ninety-eight percent of Web sites provided explicit dollar amounts as cost measures (Table 1). The majority of the Web sites reported cost measures as average charges (71 percent). Only a single Web site, however, provided explicit information on patient out-of-pocket expenses. Furthermore, only one Web site differentiated between costs for insured and uninsured individuals. On the Maine Health Data Organization Web site, consumers could navigate either as an insured patient or an uninsured patient; however, this choice determined which questions the site asked in order to calculate costs. Some Web sites listed the highest and lowest cost providers charged for a visit or a given procedure. The five Web sites providing only Medicare procedure costs indicated the median Medicare payment. Methods of comparison varied but most of the Web sites enabled comparison between hospital facilities. About one-quarter of Web sites allowed for a comparison of costs across selected counties or regions. For some sites, consumers could search for information using their zip code. Many of the sites compared provider or hospital information to state benchmarks, which allowed for comparison on a larger scale (42 percent).

Table 1 Characteristics of Web sites that publicly report cost measures

Characteristics of Web Sites | n | %*
Owner:
Owned by state health department or state hospital association | 44 | 75%
Setting:
Provided information on inpatient care | 59 | 100%
Provided information on both inpatient and outpatient care | 31 | 53%
Provided information on emergency care services | 5 | 9%
Provided information on nursing home daily room rates | 3 | 5%
Type:
Reported costs as dollar amounts | 58 | 98%
Represented costs symbolically | 4 | 7%
Measure of costs:
Reported average charges | 42 | 71%
Year of data:
Reported data from 2011 and later | 44 | 76%
Reported data from 2013 | 8 | 14%
Comparison:
Allowed comparison against other providers | 59 | 100%
Allowed comparison against state averages | 25 | 42%

Note: Categories may exceed 100 percent as Web sites may fit one or more categories

As seen in Table 2 and Appendix C, the Web sites we identified offered a wide range of cost measures to their consumers. These sites used common terminology including: charges, costs, payments, prices, and reimbursements, but sometimes used these words to mean different things. “Charges” often reflected an amount listed on a hospital charge master or the amount billed to patients or insurance companies for a visit or service. “Costs” often, although not always, referred to production costs. “Payments” or “reimbursements” referred to what the insurance company or carrier was responsible for paying to the provider or hospital. Many Web sites provided definitions or explanations so consumers could better understand their terminology and data. Some Web sites explicitly stated that the costs reported do not equate to the price that patients pay for health care services. However, none of these sites clearly indicated what patients or insurance companies are responsible for paying for the described services. Some Web sites reported that they equated prices and costs on their sites. In Table 2 we provide a sample of representative definitions from the included Web sites.

Table 2 Representative cost measures and definitions extracted from Web sites

Measure | Definition | Source
Charges
Charge | “… is the amount billed for a service.” | http://www.iowahospitalcharges.com
Average Charge | “Total charges divided by the number of discharges for the selected service.” | http://www.orpricepoint.org/Help_charge.html
Average Charge per Day | “Total charges divided by the number of inpatient days for the selected service.” | http://www.txpricepoint.org/Help_acpd.html
Average Billed Charges | “These data are available through the standard Uniform Billing form, which is utilized by hospitals to bill for their hospital charges … These data identify billed charges, not the actual payments received by the hospital.” | http://www.chiaunlv.com/Downloads/Choices/choices-2013-general-acute.pdf
Median Charge | “The midpoint between the highest and lowest charge for the selected service.” | http://www.txpricepoint.org/Help_median.html
Range of Charges | “[The] set of charges specified by a maximum and minimum value that a hospital has billed for a particular condition or procedure.” | http://www.floridahealthfinder.gov/comparecare/glossary.aspx
Cost
Costs (example 1) | “…the actual price that health plans pay hospitals for treating a specific condition or performing a procedure, and is NOT what a patient will pay.” | http://hcqcc.hcf.state.ma.us/Content/FrequentlyAskedQuestions.aspx
Costs (example 2) | “Allowed rate” of payment to health care providers.” | http://nhhealthcost.nh.gov/methodology-health-costs-consumers
Average Costs | “… based on charges adjusted to cost using the hospital's specific cost center cost-to-charge ratio.” | http://www.ahd.com/definitions/free_oputil.html
Range of Costs | “… range of costs that was reported at a hospital for a particular condition or procedure.” | http://hcqcc.hcf.state.ma.us *
Payment
Average Payment | “Total payments divided by the number of patients for the selected service. The average Medicare payment includes the base payment, diagnosis-related-group for inpatient or Ambulatory Payment Classification for outpatient and, where applicable, additional payments for graduate medical education, indirect medical education, disproportionate share, and capital in accordance with Medicare payment policies.” | http://www.mhakeystonecenter.org/definitions.htm
Out-of-pocket (OOP) | “The portion of payments for covered health services required to be paid by the patient, including co-payments, co-insurance, and deductible.” | https://riverview.org/billpay/glossary/
Reimbursements
Average Reimbursements | “… the average amount a health carrier paid. These numbers include only care covered where a company had 10 or more reported procedures in a year.” | http://doraapps.state.co.us/insurance/drg/

* Multiple specific Web sites present this definition within this Web site.

Even with the single Web site that reported out-of-pocket costs, only average out-of-pocket costs were reported. This may not reflect the actual out-of-pocket costs that a specific consumer would be responsible for paying. We did not find any Web sites that reported out-of-pocket costs that also included co-payments and deductibles that an individual consumer might have to pay based on his health plan. This is an emerging practice on semipublic reporting sites (Appendix D).

## GQ2 Are the Cost Measures Reported in a Consumer-Centered Way?

We found diverse observations in the literature about the consumer centeredness of public reports. Health care consumers desire information that is relevant, such as quality data on physicians and services and cost measures that reflect out-of-pocket expenses.24 However, publicly reported cost data that confuses rather than informs is not useful to the consumer.26

In practice, Web-based reports tend not to distinguish between facility charges and actual costs borne by consumer.27 According to Christianson et al. there's also wide variation in the information contained in these reports.28 While the quality and consumer centeredness of the health care information available on Web sites seems to be improving, a recent analysis concluded that cost reporting has not incorporated current knowledge regarding cognitive psychology and health care decisionmaking.20

### PRICE Taxonomy

Our novel taxonomy (PRICE) assesses the consumer centeredness of Web sites that publicly report health care cost data. As detailed in Table 3, our taxonomy examines these Web sites across five domains: price transparency, real comparisons, information on value, connect to care, and ease of use, and scores each domain using three criteria specific to each domain. We provide a detailed description and the source for each of the criteria in Table 3. Most of the criteria within each domain are independent of each other, but one might consider some domains hierarchical.

Table 3 PRICE taxonomy of the consumer centeredness of Web sites that publicly report costs

Domain | Criteria | Description | Source
Price transparency | Out-of-pocket costs | The data reflect a consumer's personalized out-of-pocket expenses, including insurance status, remaining deductible, and co-pay rates. | 8, 20, 29, 30
Price transparency | Timely cost data | The data are less than 3 years old. | 31, 32, Key Informants
Price transparency | Clear description of costs | The site clearly describes the type of price information being shared (e.g., costs, charges, average vs. median). | 21, Key Informants
Real comparisons | Shoppable conditions | The data include non-urgent and non-severe conditions for which consumers want prompt, high-quality attention. | 21, 20, 23,Key Informants
Real comparisons | Market comparisons | The site allows consumers to compare providers to other “relevant” providers and not just benchmarks. | 31, 32,Key Informants
Real comparisons | Customizable searches | The site has a search capability that can be customized to the consumer's wants and needs (e.g., geography, setting). | 31,Key Informants
Information on value | High-value providers | The site guides consumers to higher-value providers. | 17, 29, 31,Key Informants
Information on value | Quality comparators | The site pairs cost data with quality data (outcome or process measures) or patient experience data on the same page. | 8, 17, 21, 30, Key Informants
Information on value | Patient ratings/reviews | The site includes ratings, reviews by patients, or both. | 20, 31
Connect to care | Address/contact information | The site provides the address and contact details for an individual provider or facility. | Key Informants
Connect to care | Acceptance of new patients | The site identifies whether a provider or facility is accepting new patients and the types of insurance accepted by the provider or facility. | 31
Connect to care | Logistics | The site provides logistics, such as maps, location, directions, and information on public parking. | 20
Ease of use | Simple interface | The site uses a simple, intuitive, and easy-to-navigate user interface for sharing data. | 29-31, Key Informants
Ease of use | Understandable | The site uses plain language and understandable symbols to make relevant information accessible. | 29-32,Key Informants
Ease of use | User support | The site includes sufficient instructions, frequently asked questions, or online or telephone support. | 31, Key Informants

Price transparency is a central concept in the public reporting of cost data.5 Our taxonomy describes price transparency using three criteria: (a) out-of-pocket costs, (b) timely cost data, and (c) clear description of costs. Consumers need to know out-of-pocket costs in order to make informed decisions about providers and services. To effectively estimate out-of-pocket costs, Web sites must have the functionality to incorporate the consumer's insurance status, remaining deductible, and copayment or co-insurance rates, and out-of-pocket maximum. Timely cost data help ensure that consumers have the most recent information available to make decisions. We considered costs reported since 2011 as timely. A clear description of costs helps consumers better understand the exact nature of the price data the site is reporting (e.g., costs, charges, reimbursements), and whether the value represents a summary statistic, such as the mean or median. To make an informed decision, consumers must understand the types of data being shared. Here we focused simply on whether the site clearly defined the measure to the consumer, recognizing that a consumer's comprehension of the data may also relate to features assessed elsewhere in the taxonomy (e.g., whether the materials are presented in an understandable way). Although we did not consider it when designing the PRICE taxonomy, there's a growing belief that presenting pricing bundles or costs of episodes of care may help consumers make more informed choices.

Real comparisons is a key tenant to the public reporting of provider performance, whether it's the reporting of quality data, cost data, or both.16, 33 We describe real comparisons in terms of: (a) shoppable conditions, (b) market comparisons, and (c) customizable searches. Shoppable conditions can be subjective and include non-urgent and non-severe conditions for which consumers want prompt, high-quality attention. For these types of conditions, consumers may use cost and quality data as part of their decisionmaking.30 Market comparisons allow a user to compare a provider or facility against other ‘relevant’ providers, and not just a static benchmark. Consumers want the ability to compare options easily, and evaluating against benchmarks requires an understanding of the benchmark indicators, which is not necessarily easy for consumers.31 Customizable searches allow the user to narrow their search to those providers that meet a specific criterion, such as geographic location or setting. This ensures that search results only include providers the consumer might use.

Information on value describes whether consumers receive the maximum benefit from the resources spent. We noted whether sites identify: (a) high-value providers, (b) quality comparators, and (c) patients' ratings or reviews. Web sites that identify high-value providers use explicit labels or symbols to intentionally guide consumers to health care providers that deliver higher value care. Consumers find an explicit indicator helpful in selecting higher-value providers.17 Web sites with quality comparator functionality pair cost data with quality data, patient experience data, or both. Pairing quality data with cost data are best practice; without quality data, many consumers conclude that higher costs reflect higher quality.27 The incorporation of patients' ratings or reviews of health care providers into public reporting makes the site interactive and allows consumers to learn about the real experiences of others relating to the cost or value of providers. Most retail and travel Web sites include consumer feedback to help facilitate decisionmaking.

Connect to care is important for helping consumers make the step from decisionmaking to arranging care. Sites that facilitate access to care are those that present: (a) address/contact information, (b) information on acceptance of new patients, and (c) logistics. When a Web site provides address/contact information for a provider or facility, this helps consumers easily access care if they choose that provider or facility. Information that indicates if providers are accepting new patients and what insurance the provider accepts is also helpful. Logistics include information such as maps, location, directions, and information on public parking.

Ease of use is how easily a consumer can navigate a Web site and understand and access the data. This affects whether a consumer will return to the site for future information.34 We describe ease of use by gauging whether a Web site: (a) has a simple interface, (b) is understandable, and (c) offers user support. While much of this is subjective, we define a simple interface as one that is intuitive, easy-to-navigate, and utilizes effective Web site design principles.34

An understandable site is a site that uses plain language (i.e., language at approximately a 5^th^ grade reading level or less) and simple symbols or graphics for communicating information without biasing consumers' interpretations or actions. Simple language and symbols promote a greater comprehension of the data. User support includes clear instructions, answers to frequently asked questions, and online and telephonic assistance designed to answer common consumer questions or problems.31

The percentage agreement between our two reviewers, across all 15 criteria in the PRICE taxonomy, was 83.1 percent, with a kappa statistic of 0.66. Figure 2 shows the distribution of the sum of the 15 items included in the PRICE taxonomy across all 59 Web sites. The mean and median were 8.3 and 8, respectively, and the total ranged from a minimum of 4 to a maximum score of 11. About three-quarters of the Web sites screened (n=45) met at least half of the criteria of the taxonomy.

Figure 2 Consumer centeredness rating of Web sites using PRICE taxonomy

Figure 2: The figure shows 6 individual histograms for consumer centeredness rating of included websites. Histogram “Price transparency” shows the percentage of websites that score 0, 1, 2 and 3 score on the price transparency criteria of consumer-centeredness rating. Histogram “Real comparisons” shows the percentage of websites that score 0, 1, 2 and 3 score on the real comparisons criteria of consumer-centeredness rating. Histogram “Value for money” shows the percentage of websites that score 0, 1, 2 and 3 score on the value for money criteria of consumer-centeredness rating. Histogram “User-friendliness” shows the percentage of websites that score 0, 1, 2 and 3 score on the user-friendliness criteria of consumer-centeredness rating. Histogram “Access to care” shows the percentage of websites that score 0, 1, 2 and 3 score on the access to care criteria of consumer-centeredness rating. Histogram “Consumer-centeredness rating” shows the percentage of websites that scored 0-15 on the total consumer-centeredness rating.

The ease of use (2.6) and real comparisons (2.4) domains had the highest average count across the five PRICE domains, and information on value (0.7) and connect to care (0.8) had the lowest (Table 4). Approximately 80 percent of Web sites met two of the criteria for price transparency and about 40 percent of Web sites met all three criteria for real comparisons. For connect to care, approximately 50 percent of Web sites met only one of the three criteria. Most Web sites did well on the ease of use domain with over 70 percent meeting all three criteria.

Table 4 Count of PRICE domains

PRICE domains | Mean (SD) | 0 of 3 (%) | 1 of 3 (%) | 2 of 3 (%) | 3 of 3 (%)
Price transparency | 1.8 (0.5) | 1.7 | 19 | 80 | 0
Real comparisons | 2.4 (0.6) | 0 | 6.8 | 51 | 42
Information on value | 0.7 (0.5) | 32 | 66 | 1.7 | 0
Connect to care | 0.8 (0.7) | 35 | 49 | 15 | 0
Ease of use | 2.6 (0.7) | 1.7 | 6.8 | 19 | 73

SD = standard deviation

The percent of Web sites meeting the specific criteria for the PRICE taxonomy is listed in Table 5. Approximately 97 percent of the Web sites offered information on shoppable conditions and clearly described measures of cost. Nearly 90 percent of all the Web sites had a simple and easy-to-navigate interface, and nearly 95 percent used understandable language and symbols to make information accessible. Other criteria that more than half of the sites met include: providing timely data (80 percent), comparing relevant providers (70 percent), facilitating flexible searching for providers (73 percent), pairing cost data with quality data (68 percent), providing contact information for user support (78 percent), and providing an address and contact details for the provider or facility (64 percent).

Table 5 Percentage of Web sites meeting each criterion

Domain | Criteria | n | %
Price transparency | Out-of-pocket costs | 1 | 1.7
| Timely cost data | 47 | 80
| Clear descriptions of costs | 57 | 97
Real comparisons | Shoppable conditions | 57 | 97
| Market comparisons | 41 | 70
| Customizable searches | 43 | 73
Information on value | High-value providers | 0 | 0
| Quality comparators | 40 | 68
| Patient ratings/reviews | 1 | 1.7
Connect to care | Address/contact information | 38 | 64
| Acceptance of new patients | 0 | 0
| Logistics | 9 | 15
Ease of use | Simple interface | 53 | 90
| Understandable | 56 | 95
| User support | 46 | 78

There were several PRICE criteria that we did not commonly find on the Web sites. For example, only the New Hampshire Insurance Department site provided data on out-of-pocket expenses. None of the Web sites provided information on providers' acceptance of new patients or the type of insurance they accepted. In spite of the recent emphasis on high-value or efficient care, we found no Web sites that guided consumers to higher-value providers.