# References

1 Berwick DM, Hackbarth AD. Eliminating waste in US health care. JAMA. 2012;307(14):1513-6. [pmid: 22419800].
2 Emanuel EJ, Fuchs VR. The perfect storm of overutilization. JAMA. 2008;299(23):2789-97. [pmid: 18560006].
3 Anderson GF, Reinhardt UE, Hussey PS, et al. It's the prices, stupid: why the United States is so different from other countries. Health Aff (Millwood). 2003;22(3):89-105. [pmid: 12757275].
4 Berger ZD, Joy SM, Hutfless S, et al. Can public reporting impact patient outcomes and disparities? A systematic review. Patient Educ Couns. 2013;93(3):480-7. [pmid: 23579038].
5 Sinaiko AD, Rosenthal MB. Increased price transparency in health care--challenges and potential effects. N Engl J Med. 2011;364(10):891-4. [pmid: 21388306].
6 Preidt R. Doctor “report cards” not last word on performance [News]. 18. September. 2010. http://usatoday30.usatoday.com/yourlife/health/healthcare/doctorsnurses/2010-09-18-doctorratings_N.htm. January 2014.
7 Rabin R. The confusion of hospital pricing [News]. 23. April. 2012. http://well.blogs.nytimes.com/2012/04/23/the-confusion-of-hospitalpricing/. January 2014.
8 Harvey HB, Prabhakar AM, Gowda V, et al. Removing the veil: price transparency in interventional radiology. J Vasc Interv Radiol. 2013;24(9):1343-6. [pmid: 23973023].
9 Institute of Medicine. Crossing the Quality Chasm: A New Health System for the 21st Century [Web Page]. March. 2001. http://www.iom.edu/Reports/2001/Crossing-the-Quality-Chasm-A-New-Health-System-for-the-21st-Century.aspx. January 2014.
10 Malcolm JA Jr. First public report for physicians due this summer. Pa Med. 1992;95(5):12-4. [pmid: 1603589].
11 Epstein A. Performance reports on quality--prototypes, problems, and prospects. N Engl J Med. 1995;333(1):57-61. [pmid: 7777000].
12 Marshall MN, Shekelle PG, Leatherman S, et al. The public release of performance data: what do we expect to gain? A review of the evidence. JAMA. 2000;283(14):1866-74. [pmid: 10770149].
13 Federal Register -2006 George W. Bush Executive Orders. http://www.archives.gov/federal-register/executive-orders/2009-wbush.html.
14 Krumholz HM, Keenan PS, Brush JE Jr, et al. Standards for measures used for public reporting of efficiency in health care: a scientific statement from the American Heart Association Interdisciplinary Council on Quality of Care and Outcomes research and the American College of Cardiology Foundation. J Am Coll Cardiol. 2008;52(18):1518-26. [pmid: 19017522].
15 Fung CH, Lim YW, Mattke S, et al. Systematic review: the evidence that publishing patient care performance data improves quality of care. Ann Intern Med. 2008;148(2):111-23. [pmid: 18195336].
16 Ketelaar NA, Faber MJ, Flottorp S, et al. Public release of performance data in changing the behaviour of healthcare consumers, professionals or organisations. Cochrane Database Syst Rev. 2011;(11). CD004538. [pmid: 22071813].
17 Hibbard JH, Greene J, Sofaer S, et al. An experiment shows that a well-designed report on costs and quality can help consumers choose high-value health care. Health Aff (Millwood). 2012;31(3):560-8. [pmid: 22392666].
18 Australian Commission on Safety and Quality in Health Care (ACSQHC). http://www.safetyandquality.gov.au/ [Web Page]. January 2014.
19 Keselman A, Logan R, Smith CA, et al. Developing informatics tools and strategies for consumer-centered health communication. J Am Med Inform Assoc. 2008;15(4):473-83. [pmid: 18436895].
20 Sinaiko AD, Eastman D, Rosenthal MB. How report cards on physicians, physician groups, and hospitals can have greater impact on consumer choices. Health Aff (Millwood). 2012;31(3):602-11. [pmid: 22392672].
21 Kullgren JT, Duey KA, Werner RM. A census of state health care price transparency Web sites. JAMA. 2013;309(23):2437-8. [pmid: 23780454].
22 O'Neil S SJ, Simon S. Environmental scan of public reporting programs and analysis: final report: Mathematica Policy Research report submitted to the National Quality Forum. Washington (DC). National Quality Forum. 2010. Sep. 30.
23 Robert Wood Johnson Foundation. 2013. http://www.rwjf.org/. January 2014.
24 Yegian JM, Dardess P, Shannon M, et al. Engaged patients will need comparative physician-level quality data and information about their out-of-pocket costs. Health Aff (Millwood). 2013;32(2):328-37. [pmid: 23381526].
25 Informed Patient Institute (IPI) Nonprofit organization.
26 James J. Public Reporting on Quality and Costs. Do report cards and other measures of providers' performance lead to improved care and better choices by consumers?. http://healthaffairs.org/healthpolicybriefs/brief_pdfs/healthpolicybrief_65.pdf. 8 March 2012.
27 Bardach NS, Hibbard JH, Dudley RA. Users of Public Reports of Hospital Quality: Who, What, Why, and How? An aggregate analysis of 16 online public reporting Web sites and users' and experts' suggestions for improvement. AHRQ Publication No. 12-0016-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
28 Christianson JB, Volmar KM, Alexander J, et al. A report card on provider report cards: current status of the health care transparency movement. J Gen Intern Med. 2010;25(11):1235-41. [pmid: 20625849].
29 Mehrotra A, Hussey PS, Milstein A, et al. Consumers' and providers' responses to public cost reports, and how to raise the likelihood of achieving desired results. Health Aff (Millwood). 2012;31(4):843-51. [pmid: 22459922].
30 Robert Wood Johnson Foundation. Consumer Beliefs and Use of Information about Health Care Cost, Resource Use, and Value Findings from Consumer Focus Groups. 2012. http://www.rwjf.org/en/research-publications/find-rwjf-research/2012/10/consumer-beliefs-and-use-of-information-about-health-care-cost--.html.
31 Catalyst for payment reform (An independent, national nonprofit organization for employers and other purchasers committed to a higher-value health care system)- Comprehensive Specifications for the Evaluation of Transparency Tools. http://www.catalyzepaymentreform.org/images/documents/Price_Transparency_Specifications.pdf.
32 Quality Alliance Steering Committee. Recommendations for Reporting Cost and Price Information to Consumers. 2008. http://www.healthqualityalliance.org.
33 Faber M, Bosch M, Wollersheim H, et al. Public reporting in health care: how do consumers use quality-of-care information? A systematic review. Med Care. 2009. Jan. 2009;47(1):1-8. [pmid: 19106724].
34 Hassan L, A E. Assessing the quality of web sites. Applied Computing and Informatics. 2011. 2011;9(1):11-29.
35 Tu HT, Lauer JR. Impact of health care price transparency on price variation: the New Hampshire experience. Issue Brief Cent Stud Health Syst Change. 2009;(128):1-4. [pmid: 19908405].