# Objective

In this report, we examine the practices of public reporting of cost measures in health care and the extent to which this reporting is consumer-centered. Broadly, this report is focused on the public reporting of health care costs as a means to promote price transparency. Price transparency are efforts aimed at informing health care consumers (and those who make decisions on their behalf) about the expense they will incur. Price transparency is normally targeted before consumers seek care so they can be empowered to make informed treatment decisions. In this way, our aim is to inform researchers, policymakers, and health care providers about cost reporting practices that might effectively guide patients and other consumers in making decisions about health care.

The scope of this review was limited to services provided by individual health care providers (such as physicians and other providers who charge for their services) and health care facilities (including clinics, hospitals, skilled nursing facilities, home health care providers, and nursing homes) in the United States As such, it excludes public reporting on products such as pharmaceuticals and medical devices, health care insurance plans, and foreign practices. Furthermore, we excluded cost data reported by either a single provider or single facility, as these data do not allow consumers to make comparisons. In addition, we considered cost comparisons to a national or state benchmark insufficient for this report. Our key definitions are in Box 1.

Box 1 Key definitions we used to guide our review

Public reporting of cost data: Data on health care costs of providers that are publicly available to a broad audience of consumers (either free of charge, at a nominal cost, or granted based on group affiliation) and that allow for comparisons within a defined geographic area.

Consumer: Any actual or potential recipient of health care services and their families or advocates who act on their behalf.

Cost measure: A financial measure of cost, charge, reimbursement, payment, or out-of-pocket expenses associated with a visit to a health care provider.

This report is not intended to be a critique of current practices. Similarly, we did not determine which cost measures providers should use, the procedures they should report on, or exactly how consumers should compare providers. Rather, we documented current practices and identified ways that the public reporting of costs could be more consumer centered. We were particularly comprehensive in the number of sites reviewed and the amount of detail described. As this is fundamentally a review, many of the findings exist elsewhere in the literature.