# Methods

We abstracted the primary data for this study in December 2013 from Web sites that publicly report cost measures. Our targeted literature review and Key Informants helped us identify these sites, as well as the taxonomy we used to assess consumer centeredness (PRICE). We list the methods and results of the targeted literature review in Appendix A.

## Engagement

Consistent with standard EPC practices, AHRQ and our Key Informants provided input to help guide the research and writing of this report. We also sought input from peer reviewers and made the report available for public comment.

We conducted an Internet search of relevant professional organizations to identify Key Informants with expertise in this topic. We initially identified 10 individuals, seven of which agreed to participate. Following AHRQ review and determination of conflicts of interest, we set up two group interviews with the seven Key Informants and provided them with a copy of the proposed GQs. On the first call, in December 2013, we gave an overview of the project and shared our working definitions for key terms. We also invited the Key Informants to share their knowledge of relevant literature and public reporting Web sites, and discussed tools available to measure the consumer centeredness of public reporting Web sites. On the second call, in January 2014, we updated the Key Informants on the project's status, and reviewed our data abstraction instrument, taxonomy for consumer centeredness, and list of semipublic Web sites. We recorded and transcribed the interviews and distributed a summary to all participants. Where possible, we crosschecked Key Informant interviews against available literature and other sources.

We invited Peer Reviewers to provide written comments on a draft report based on their experience in research and practice. We considered these comments when preparing the final report. AHRQ posted the draft report on its Web site for 4 weeks to elicit public comment.

### GQ 1 What Measures of Costs About Health Care Providers Have Been Publicly Reported?

We reviewed public reporting Web sites that compared providers within a geographic area, rather than Web sites where a single provider reported its own costs (with or without presenting a benchmark). As this project used evidence synthesis techniques rather than primary data collection, we needed to identify a set of candidate public reporting Web sites. We located these Web sites with the help of AHRQ and Key Informants and through our targeted literature review.

We analyzed public reporting Web sites in three phases. Similar to a literature review, we performed the equivalent of a title/abstract screen phase (where we reviewed all sites initially), a full article screen phase (where we conducted a detailed review of the content of the sites), and a data abstraction phase (where we reviewed the content of sites based on predetermined criteria) (Box 3). We used Microsoft Excel to manage the data from our environmental scan, including the links to the Web sites, during both the screening and data abstraction phases.

Box 3 Inclusion and exclusion criteria for Web sites review

Stage of review | Inclusions | Exclusions
First-phase screening | ✓ Any measure of cost of health care delivery; ✓ Measures of utilization (readmission rates, length of stay) | - No measure of any kind of cost; - Only shows potential costs for purchasing health insurance plans
Second-phase screening | ✓ Cost measures met the following definition: A financial measure of cost, charge, reimbursement, payment, or out-of-pocket expenses associated with a visit to a health care provider or facility; ✓ Data on health care costs of providers allowing for comparisons within a defined geographic area | - Only quality measures provided; - Not available to the public (requires a login or membership)

In the first phase, two independent reviewers screened Web sites for inclusion. They included a Web site if there were any indicators of a cost assigned to a health care provision or any measure of resource utilization. They excluded a Web site if they both agreed it met one or more of the exclusion criteria (Box 3). We resolved conflicts between reviewers by consensus. One investigator (JB) made the final decision on any persisting disagreements. During this initial review, we prioritized financial measures of costs (i.e., measures involving dollar amounts) and the graphical or pictorial representation of such data. However, we also initially included measures of resource utilization when we thought the data were acting as a proxy measure for costs.

During the second phase, two independent reviewers (YC and TK) screened the Web sites for inclusion using explicit definitions of the following terms: “public reporting of cost data,” “consumer,” and “cost measure.” We tightened our definition of “cost measure” to include only those Web sites reporting financial measures of costs. Hence, we excluded resource utilization measures because we could not find a consistent definition, and because many such indicators (e.g., use of antibiotics or length of stay) could also be quality indicators. We recorded a detailed reason for inclusion or exclusion. If the reviewer was unsure about a Web site, or if there was disagreement between reviewers, the lead investigator (JB) made the final decision.

In the final abstraction phase, one reviewer independently abstracted data for each site using a standardized data abstraction form and evaluated the consumer centeredness of the Web site using the taxonomy described in the results section. We conducted a validity test to ensure consistency of abstraction between the independent reviewers (YC and TK) for five Web sites. We resolved inconsistencies through consensus before moving forward with the review of the entire database. For each site, the reviewers (YC and TK) extracted the following information: the Web address, the owner of the Web site, the setting of health care delivery for which information is reported, the presentation of costs, the type of cost measures, the year of reported data, and the level of comparisons. The Web address is the URL for the site, and the owner of the Web site is the party responsible for populating and maintaining the Web site. The settings of health care delivery included, but were not limited to, inpatient, outpatient, nursing home, or emergency room settings. Web sites presented cost as dollar values, unique symbols representing cost measures, or graphs containing cost information. Reviewers extracted the type of cost measures, which included, but were not limited to, average costs, average charges, average reimbursements, and average out-of-pocket expenses. Lastly, reviewers extracted the level at which the Web site can display comparisons (e.g., between facilities, counties, individual providers, or against state and national benchmarks).

### GQ 2 Are the Cost Measures Reported in a Consumer-Centered Way?

To assess if publicly reported measures of costs are consumer centered, we developed and applied a novel taxonomy described below in Table 3. We developed this taxonomy using three sources: discussions with our Key Informants, a targeted literature review (Appendix A), and our direct observation and discussion of current public reporting practices. Two reviewers (YC and TK) abstracted a combination of objective and subjective data pertaining to consumer centeredness from the public reporting Web sites, and resolved disagreements by engaging the entire study team. We calculated summary measures for the overall taxonomy and across key domains to gauge which aspects of current public reporting practices are most consumer centered. We did not weight the elements of the taxonomy or domains, but acknowledge that a simple summation implies equal importance of all factors.