# Guiding Questions

In collaboration with AHRQ, we developed two broad guiding questions (GQs). We used additional sub-questions to help define the scope of each of the GQs (Box 2). We refined our approach as we gathered more data about public reporting. Discussions with AHRQ and with Key Informants also guided this study.

Box 2 Guiding Questions (GQ) for the study

GQ 1: What measures of costs about health care providers have been publicly reported?
a. Who produces these reports and where are they available?
b. For what services are costs reported?
c. At what level are the data aggregated (e.g., provider, facility)?
d. How are the cost data reported (e.g., dollar amounts, symbols, graphs)?
e. How are the costs of providers compared (e.g., how many facilities, regional vs. national comparisons)?

GQ 2: Are the cost measures reported in a consumer-centered way?
a. How are consumers instructed to use the data?
b. What techniques are used to guide consumers to interpret the data appropriately?
c. Is there evidence that consumers use the data?
d. Are the data relevant to consumers making health care decisions?
e. Are the data easily accessible and presented in a consumer-friendly way?

GQ1 identifies the entities that produced these Web-based cost reports, where the reports appeared, the services they reported, the level of aggregation in the reports, how they reported cost data (e.g., dollar amounts, symbols, graphs), and how they compared costs across providers.

GQ2 assesses whether the practices for public reporting of costs are consumer centered. Guided by AHRQ and our Key Informants, we defined consumer-centered public reporting as an activity that helps consumers' compare and choose health care providers. Therefore, we developed a definition of consumer-centered public reporting and created a novel taxonomy (PRICE) to evaluate it. We used the published literature to learn how and why consumers use cost data in their decisionmaking (e.g., to avoid additional cost, to assess quality).

Given the lack of research examining whether public reporting of costs is consumer centered, and how this affects health care choices, we needed some flexibility in our GQs. For GQ2 we realized that our sub-questions were not comprehensive enough, so we expanded them.

Furthermore, our study protocol included a third GQ regarding confounding factors that may occur when consumers use publicly reported cost data. Given the lack of studies focusing on this topic, we address this question in the gaps analysis section of this report.