# Peer Reviewers

Prior to publishing the final evidence report, we sought input from independent Peer Reviewers who did not have financial conflicts of interest. However, the conclusions and synthesis of the scientific literature we presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, we may retain individuals with potential nonfinancial conflicts. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Naomi S. Bardach, M.D., M.A.S.
  University of California, San Francisco
  San Francisco, CA
- Jessica Greene, Ph.D., M.P.H.
  The George Washington University School of Nursing
  Washington, D.C,
- Ateev Mehrotra, M.D., M.P.H.
  Harvard Medical School
  Boston, MA
- Barbara A. Rudolph, Ph.D., M.S.S.W.
  University of Wisconsin-Madison
  Madison, WI
- Anna D. Sinaiko, Ph.D.
  Harvard School of Public Health
  Boston, MA