# Key Informants

In designing the study questions, the EPC consulted a panel of Key Informants who represent subject experts and end-users of research. Key Informant input can inform key issues related to the topic of the technical brief. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Chuck Alston
  MSLGROUP
  Washington, D.C.
- Carol Cronin, M.S.W., M.S.G.
  Informed Patient Institute
  Annapolis, MD
- R. Adams Dudley, M.D., M.B.A.
  UCSF Health Services Informatics Lab
  University of California
  San Francisco, CA
- Judith H. Hibbard, Dr.P.H.
  Health Policy Research Group in ISE
  University of Oregon
  Eugene, OR
- Peter S. Hussey, Ph.D.
  Health Services Delivery Systems
  RAND
  Boston, MA
- Harold Luft, Ph.D.
  Palo Alto Medical Foundation Research Institute
  University of California San Francisco
  San Francisco, CA
- Shoshanna Sofaer, Dr.P.H.
  School of Public Affairs, Baruch College
  New York, NY