# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officers, Drs. Monique D. Cohen and Stephanie Chang in the Center for Evidence and Practice Improvement, and Dr. Celeste M. Torio in the Center for Delivery, Organization, and Management. We also would like to thank Johns Hopkins EPC director Dr. Eric Bass for his valuable insight throughout the project. We extend our appreciation to key informants, all of whom provided thoughtful advice and input on the calls.