# Background

Health care in the United States has become unaffordable for many consumers.1 While national health care reports do not indicate how the cost of health care in the United States compares to other nations,2 it's clear that this unaffordability reflects the relatively high (and increasingly variable) prices paid in the United States for services.3 The Patient-Protection and Affordable Care Act of 2010 has applied many measures to curb the costs and improve the quality of health care in the United States. These reforms, in part, are placing increased emphasis on public reporting.4

Primarily it is thought that publicly reporting on the cost and quality of health care providers helps consumers make well-informed decisions about care. Public reporting may also improve how health care resources are consumed by promoting the use of treatments that are effective. This being said, the mechanism of action linking public reporting and outcomes may not necessarily require consumer action. Public reporting may promote competition among providers and/or health care systems that care about their reputation or bottom line. Likewise, health insurance plans or self-insured firms may use public reporting data to make more effective decisions on behalf of their members or employees.

Public reporting on health care quality has become increasingly prevalent over the last decade, while much less is known about the frequency and content of public reporting of costs. Cost reporting has become even more important recently as more consumers are choosing high-deductible health plans and plans with reference-based pricing, leaving consumer more exposed to the costs of care.5-7 Increased transparency regarding health care prices and costs could help consumers make more prudent and cost-effective health care decisions.8

For cost reporting to be truly effective, however, these reports need to be consumer centered. This report aims to inform both research and practice by documenting current public reporting of costs practices and assessing if these practices are consumer centered.

## Public Reporting

The Institute of Medicine's (IOM) Crossing the Quality Chasm report shaped U.S. health care policy reform in the 21st century.9 The IOM challenged the U.S. health care system to become increasingly safe, timely, efficient, effective, equitable, and patient centered in order to improve quality. Many of the strategies described in the IOM report involve creating a transparent health care system to better inform consumers and empower them to make better decisions. As a result, we've seen an increased focus in both research and practice to find ways to improve transparency, promote patient-centered care, and enhance consumer decisionmaking (goals that are at the core of health care reform). However, the best path to achieve these goals is uncertain.

One approach to improve transparency has been public reporting, a quality improvement strategy that emerged in the early 1990s.10, 11 Public reporting refers to an organized effort to provide data about health care services to help consumers and other stakeholders make better-informed decisions about health care. Ideally, public reporting could provide information on the cost and quality of health care for a wide variety of providers. Such information would include cost indicators of price or resource utilization, quality indicators of outcomes and processes, as well as other relevant indicators (e.g., conflicts of interest) associated with physicians, hospitals, clinics, payers, or other health care organizations.

Since the start of public reporting in health care, hospital- and plan-based measures have predominated, with relatively little public reporting about health-care professionals.12 A renewed interest in public reporting on health care professionals came with Physician Compare-a federal program that allows consumers to compare physicians and other health care professionals associated with Medicare. However, few data are available on how or if individuals choosing primary care providers use public reporting.

Public reporting is often motivated by wide variations in health care utilization, both geographically and otherwise, as it aims to make such variations more transparent to consumers. Additionally, public reporting may encourage providers to pursue quality improvement in order to elevate their public image and attract consumers. However, the most common reason for public reporting is to help consumers choose the best health care. Ideally, public reporting sets in motion a virtuous cycle by which consumers identify the most suitable health care services and providers for their needs, and providers modify their practice to conform to the needs of health care consumers. Thus, public reporting can help realign the U.S. health care system by removing gaps between consumers' needs and the actions of health care providers. However, one can also imagine (by analogy with other markets) ways in which publicly reported data on providers might encourage decisions that may not be in the best interest of consumers. For example, public reporting may encourage consumers to focus on reputation rather than quality.

The public-reporting field became richer in 2006 when the Bush administration issued an executive order mandating price transparency in health care. As a result, various federal, state, and private approaches have attempted to improve price transparency. The Leapfrog Group introduced measures that address costs, and the Centers for Medicare and Medicaid Services implemented measures on health care efficiency, based in part on recommendations by the National Quality Forum. In addition, there are multiple state and private sector programs evaluating health care efficiency. Even though efficiency (encouraging higher value versus cost) is not the only goal of price transparency, it was the most prevalent interpretation in the early years following this presidential order. Thus, efficiency served as a useful common ground for establishing agreed-upon terminologies and definitions as public reporting of costs became widespread.14

Evidence regarding the overall effect of public health care quality and cost reporting has been mixed. Fung et al. concluded that public reporting stimulates quality improvement, but evidence is lacking about its impact on process or outcome measures.15 Similarly, Ketelaar et al. found insufficient evidence to judge whether public reporting changes the behaviors of consumers, providers, or organizations.16 Berger and colleagues reviewed the literature on the relationship between public reporting and patient-related outcomes.4 They found limited but supportive evidence that public reporting has a favorable effect on outcomes, particularly in nursing homes. The authors found little evidence supporting claims that public reporting has an impact on disparities or outcomes in the outpatient setting.

## Cost Measures and Consumer Centeredness

Compared to quality, there's a paucity of literature on the public reporting of health care costs. Therefore, little is known about which entities are reporting costs, what measures they use, and how they tailor these to consumers. Similarly, how individuals make use of cost information is unclear. For example, while there have been some experimental data on how cost reporting impacts consumers,17 there's a paucity of evidence demonstrating whether the data alter consumers' health care choices. Furthermore, it's unclear exactly how health care consumers use publicly reported cost data (e.g., is it used to supplement materials from other sources or as their sole source of information).

The more fundamental question regarding publicly reported cost data are how and where do consumers most commonly access this information. Again, the work of Hibbard and colleagues offers some insights into this question, but there's a real paucity of evidence on how consumers access or use this information.17

To better understand how or if consumers use this information, we need to assess whether this information is consumer centered via surrogate and/or process outcomes. A broad definition of “consumer centered” is “having respect for, and being responsive to the preferences, needs, and values of patients and consumers”. For publicly reported cost data to have an impact on consumers and/or the health care system, it should address the consumers' primary need to be better informed so he or she can make better decisions about health care services. Consumer-centered public reporting must also use effective strategies to communicate data to consumers.19 Data and information must be shared in a way that encourages and supports patients, consumers, and their caregivers to participate in decisionmaking.20 Presently, it is unclear as to whether public reporting helps consumers chose health care providers. This may be due to deficiencies in the content on Web sites, or their design, or accessibility. We anticipate, however, that advances in measurement, data collection, and information technology should allow for more consumer-centered public reports.20

There are limitations to defining consumer centeredness by a combination of surrogate and process outcomes. The advantages to using consumer-based endpoints (such as the number of times consumers access public-reporting Web sites, or how the data affects consumer actions) or health system measures (such as reductions in out-of-pocket or total health care costs) are clear. However, this only tells us which approaches are preferable, not why they are preferable. Furthermore, such approaches only work if there are sufficient numbers of consumers using public-reporting Web sites. In spite of these limitations, however, the goal of using surrogate and process outcomes to describe consumer centeredness is to stimulate research and practice in a way that leads to improvements in the design and implementation of publicly reported cost data.