# Characteristics of Semipublic Web Sites

To supplement our review of public Web sites that report on health care costs, we sought additional information on semipublic sites that report on health care costs. In contrast to public Web sites, semipublic Web sites may be better able to offer consumers the individualized cost information they need for decisionmaking. Private companies (e.g., health plans or third party vendors) own most semipublic Web sites. Through our targeted literature review and Key Informant interviews, we identified five vendors that report cost data to enrolled clientele. In these examples, consumers are able to access cost information via a personalized Internet login if their health plan or employer subscribes to (i.e., subsidizes) the vendors' services (Table D1).

Table D1 Examples of semipublic Web sites reporting health care costs

Vendor | Setting | Measures | Comparison | Subscription
Castlight Health www.castlighthealth.com | Outpatient | Reference based pricing, out-of-pocket costs | Facility, provider | Employer subscription
HealthSparq www.healthsparq.com | Inpatient, outpatient, urgent care, emergency room | Total cost estimates, professional facility and ancillary fees, out- of-pocket estimates | Facility and/or provider | Health plan or employer subscription
Truven Health Analytics www.truvenhealth.com | Inpatient, outpatient | Total cost estimates, out-of-pocket costs estimates | Facility, provider, geographic region | Health plan or employer subscription
Change Healthcare www.changehealthcare.com | # | # | # | Health plan or employer subscription
ClearCost Health www.clearcosthealth.com | # | # | Provider | Health plan, union or employer subscription
Compass www.compassphs.com | Outpatient | # | # | Employer, individual or family subscription

#=insufficient data in public domain to determine

The specifics of what vendors offer are largely unknown because their products are proprietary. Based on their advertisements, vendors offer consumers online platforms that provide educational material and personalized health care cost information. Some of the vendors also offer in-person, e-mail, and phone consulting services to consumers. All vendors listed in Table A1 offer didactic material so their consumers can interpret and use the cost information. The informational material includes definitions of common terms, an explanation of insurance coverage, an overview of the health care system and its navigation, and tutorials on medical billing. These are all intended to be of value to the consumer.

The vendors also provide consumers with individualized cost information based on the consumer's chosen health plan. They often break down costs into total cost estimates and out-of-pocket estimates. Depending on the platform, consumers can also compare the in-network and out-of-network costs for inpatient, outpatient, urgent, and emergency department care. Within these care settings, the vendors report on costs for medical treatments, procedures, imaging tests, and laboratory tests. One vendor, Healthsparq, also breaks down costs by professional, ancillary, and facility fees. Consumers can compare costs across facilities, providers, zip codes, and geographic regions. They have access to providers' contact information and maps to facilitate travel. Consumers can also receive updates on their accumulating costs for the year to assist with budgeting. In addition to cost data, consumers also receive quality data so they can better gauge the value of the care they receive. Another vendor, Change Healthcare, states that it tailors recommendations based on consumers' preferences regarding cost, quality, and convenience. The vendors typically market their products to health plans and employers that are interested in reducing their enrollees' or employees' health care costs. It's unclear how much a consumer's health plan or employer pay for these services. The vendors advertise that the services are a good return on investment because they improve consumer health literacy, increase engagement, and reduce costs (for health plans, employers, and consumers). Compass, another of the five vendors we reviewed, also offers services to individuals and families, independent of a health plan or an employer. The annual service fee for an individual is $108 and for a family of up to eight members is $215. To promote the service, they advertise that Compass members save an average of $620 a year by avoiding overpriced medical car.