# Characteristics of Included Web Sites

# | Owner | Setting | Type | Measure of Cost | Year | Comparison | Consumer Centeredness
# | Owner | Setting | Type | Measure of Cost | Year | Comparison | P | R | I | C | E | SUM
95. | Florida Agency for Health Care Administration | Inpatient, outpatient | Dollar amount | Charge (range) | 2012-2013 | Hospital | 2 | 3 | 1 | 2 | 3 | 11
228. | Virginia Health Information | Inpatient | Symbols | Charges (average) | 2012 | Hospital | 2 | 3 | 1 | 2 | 3 | 11
118. | Arkansas Hospital Association | Inpatient | Dollar amount | Charges (average) | 2012 | Hospital | 2 | 2 | 2 | 1 | 3 | 10
81. | State of Colorado | Inpatient, outpatient | Dollar amount | Charges, reimbursements (average) | 2011 | Hospital | 2 | 3 | 1 | 1 | 3 | 10
109. | Illinois Department of Public Health | Inpatient, outpatient, emergency | Dollar amount | Charge (median) | 2011-2012 | Hospital, state, and national | 2 | 3 | 1 | 1 | 3 | 10
125. | Iowa Hospital Association | Inpatient, outpatient | Dollar amount | Charges (average, median) | 2012-2013 | Hospital and state | 2 | 3 | 1 | 1 | 3 | 10
146. | Montana Hospital Association | Inpatient, outpatient | Dollar amount | Charges (average, median) | 2012 | Hospital, regional, and state | 2 | 3 | 1 | 1 | 3 | 10
158. | Nebraska Hospital Association | Inpatient | Dollar amount | Charges (average, median) | 2012-2013 | Hospital, regional, and state | 2 | 3 | 1 | 1 | 3 | 10
37. | Nevada Hospital Association | Inpatient, emergency | Dollar amount | Charges (average, median, range) | 2012 | Hospital, county, and state | 2 | 3 | 1 | 1 | 3 | 10
209. | South Dakota Association of Healthcare Organizations | Inpatient | Dollar amount | Charges (average, median) | 2012 | Hospital and state | 2 | 3 | 1 | 1 | 3 | 10
53. | Utah Hospitals & Health Systems Association | Inpatient | Dollar amount | Charges (average, median) | 2011 | Hospital, county, and state | 2 | 3 | 1 | 1 | 3 | 10
227. | Virginia Health Information | Outpatient | Dollar amount | Charges (median) | 2011 | Hospital and state | 2 | 3 | 0 | 2 | 3 | 10
223. | Virginia Hospital and Healthcare Association | Inpatient | Dollar amount | Charges (average, median) | 2012 | Hospital, state, and regional | 2 | 3 | 1 | 1 | 3 | 10
232. | Washington State Hospital Association | Inpatient | Dollar amount | Charges (average, median) | 2012 | Hospital, county, and state | 2 | 3 | 1 | 1 | 3 | 10
240. | Wisconsin Hospital Association | Inpatient, outpatient, emergency | Dollar amount | Charges (average, median) | 2012-2013 | Hospital, county, and state | 2 | 3 | 1 | 1 | 3 | 10
236. | Wisconsin Hospital Association Information Center | Inpatient, outpatient, emergency | Dollar amount | Charges (average, median), daily rate (average) | 2012-2013 | Hospital county, and state | 2 | 3 | 1 | 1 | 3 | 10
59. | American Hospital Directory, Inc. | Inpatient, outpatient | Dollar amount | Charges and costs (average) | 2012 | Hospital | 2 | 2 | 1 | 2 | 3 | 10
42. | Arizona Department of Health Services | Inpatient, outpatient | Dollar amount | Charges, costs (average) | 2011 | Hospital, state, and national | 2 | 3 | 1 | 0 | 3 | 9
15. | California State Government | Inpatient, outpatient | Dollar amount, symbols | Charges (average) | 2012 | Hospital and state | 2 | 2 | 0 | 2 | 3 | 9
32. | Greater Detroit Area Health Council | Inpatient, outpatient | Dollar amount | Payment (median) | 2010-2011 | Hospital | 2 | 3 | 1 | 0 | 3 | 9
60. | Healthy York County Coalition | Inpatient, emergency | Dollar amount | Charges (average) | 2012 | Hospital | 2 | 1 | 1 | 2 | 3 | 9
13. | Maine Health Data Organization | Inpatient, outpatient | Dollar amount | Charges (median), payments | 2010 | Hospital | 2 | 3 | 0 | 1 | 3 | 9
143. | State of Minnesota | Inpatient, outpatient | Dollar amount | Costs (average, median, range) | 2011-2012 | Hospital | 2 | 2 | 0 | 2 | 3 | 9
38. | Ohio Department of Health | Inpatient, outpatient | Dollar amount | Charges (average, median, range) | 2010 | Hospital | 2 | 3 | 1 | 1 | 2 | 9
182. | Oregon Association of Hospitals and Health Systems | Inpatient | Dollar amount | Charges (average, median) | 2012-2013 | Hospital, county, and state | 2 | 2 | 1 | 1 | 3 | 9
215. | Texas Hospital Association | Inpatient | Dollar amount | Charges (average, median) | 2012 | Hospital, county, and state | 2 | 2 | 1 | 1 | 3 | 9
248. | Utah Department of Health | Inpatient | Dollar amount | Charges (average) | 2011 | Hospital, state, national | 2 | 3 | 1 | 0 | 3 | 9
243. | Wyoming Hospital Association | Inpatient | Dollar amount | Charges (average, median) | 2011-2012 | Hospital, county, and state | 2 | 2 | 1 | 1 | 3 | 9
61. | Aligning Forces Humboldt | Inpatient | Dollar amount | Payment (median) | 2010-2011 | Hospital | 2 | 3 | 1 | 0 | 3 | 9
63. | Arizona Dept. of Health Services | Inpatient | Dollar amount | Charges (average) | 2012 | Hospital | 2 | 2 | 0 | 1 | 3 | 8
96. | Florida Agency for Health Care Administration | Nursing home | Dollar amount | Daily rate | NA | Provider | 1 | 2 | 0 | 2 | 3 | 8
251. | Kentucky Hospital Association | Inpatient, outpatient | Dollar amount | Charges (median), price (range) | 2012 | Hospital and state | 2 | 2 | 1 | 0 | 3 | 8
128. | Louisiana Hospital Association | Inpatient, outpatient | Dollar amount | Charge (range) | 2009 | Hospital | 1 | 3 | 1 | 0 | 3 | 8
16. | Commonwealth of Massachusetts | Inpatient, outpatient | Dollar amount, symbols | Costs (median, range) | NA | Hospital | 1 | 3 | 1 | 1 | 2 | 8
21. | Healthy Memphis Common Table | Inpatient, outpatient | Dollar amount | Payment (average) | 2011-2012 | Hospital | 2 | 3 | 0 | 0 | 3 | 8
137. | Michigan Health and Hospital Association | Inpatient, outpatient | Dollar amount | Charges, payment (average) | 2011-2012 | Hospital | 2 | 2 | 0 | 1 | 3 | 8
144. | Minnesota Hospital Association | Inpatient, outpatient | Dollar amount | Charges (average, median), daily rate (average) | 2012 | Hospital, regional, and state | 2 | 2 | 1 | 0 | 3 | 8
214. | Tennessee Hospital Association | Inpatient | Dollar amount | Charges (average, median, range) | 2010-2011 | Hospital | 2 | 1 | 1 | 1 | 3 | 8
55. | The Commonwealth Fund | Inpatient | Dollar amount | Charges, payments (average) | 2011 | Hospital, state, and national | 2 | 2 | 1 | 1 | 2 | 8
35. | The New Hampshire Insurance Department | Inpatient, outpatient | Dollar amount | Out-of-pocket, payments (insurance, combined) | NA | Provider | 2 | 2 | 0 | 1 | 3 | 8
225. | Virginia Health Information | Inpatient | Dollar amount | Charges, costs (average) | 2011 | Hospital, regional, state, and national | 2 | 2 | 1 | 0 | 3 | 8
190. | Patient Choice (Medical), Wisconsin | Inpatient, outpatient | Dollar amount | Charges (median, range) | 2011 | Hospital | 2 | 2 | 1 | 1 | 2 | 8
85. | West Virginia Health Care Authority | Inpatient, outpatient | Dollar amount | Charges (average, total) | NA | Hospital | 1 | 3 | 1 | 0 | 3 | 8
247. | Utah Hospital Association and Utah Department of Health | Inpatient, outpatient | Dollar amount | Charges (average, median) | 2011 | Hospital, county, regional, and state | 2 | 2 | 1 | 0 | 3 | 8
8. | Clear Health Costs | Inpatient, outpatient | Dollar amount | Costs (range) | NA | Hospital and provider | 1 | 3 | 0 | 1 | 3 | 8
163. | The New Jersey Hospital Association | Inpatient | Dollar amount | Charges (average, median) | 2006 | Hospital, county, and state | 1 | 2 | 1 | 1 | 2 | 7
246. | New York State Department of Health | Inpatient, outpatient | Dollar amount | Charge, cost (average, median) | 2011 | Hospital | 2 | 2 | 0 | 0 | 3 | 7
194. | Pennsylvania Health Care Cost Containment Council | Inpatient | Dollar amount, symbols | Charges (average) | 2009 | Hospital | 1 | 3 | 1 | 0 | 2 | 7
216. | UCompare Holdings, LLC | Inpatient | Dollar amount | Payments (average) | NA | Hospital | 0 | 2 | 1 | 2 | 2 | 7
77. | University of Nevada and Center for Health Information Analysis | Inpatient, outpatient | Dollar amount | Billed charges (average) | 2007-2011 | Hospital | 2 | 2 | 1 | 0 | 2 | 7
252. | Illinois Department of Public Health | Nursing home | Dollar amount | Daily rate (average) | 2006 | Provider | 1 | 2 | 0 | 1 | 2 | 6
14. | State of Maine | Inpatient, outpatient | Dollar amount | Costs (average) | 2009 | Hospital | 1 | 2 | 0 | 0 | 3 | 6
20. | Utah Department of Health | Inpatient | Dollar amount | Charges (average) | 2011 | Hospital and state | 2 | 2 | 1 | 0 | 1 | 6
157. | Center for Health Information Analysis | Inpatient, outpatient | Dollar amount | Charges (total, average), daily rate (average) | 2013 | Hospital | 2 | 2 | 0 | 0 | 2 | 6
264. | North Carolina Hospital Association | Inpatient | Dollar amount | Charges (average) | 2012 | Hospital | 2 | 1 | 0 | 0 | 2 | 5
90. | State of Vermont | Inpatient, outpatient | Dollar amount | Charges (average) | 2011 | Hospital | 2 | 2 | 0 | 0 | 1 | 5
183. | State of California | Inpatient, outpatient | Dollar amount | Prices (average) | 2013 | Hospital | 2 | 1 | 0 | 0 | 1 | 4
162. | New Jersey Health Care Quality Institute | Inpatient | Dollar amount | Charges (average) | 2009 | Hospital and state | 1 | 2 | 0 | 0 | 1 | 4
155. | North Dakota Department of Health | Nursing facility | Dollar amount | Daily rates (average) | 2011 | Facility | 1 | 2 | 0 | 1 | 0 | 4

#=Web site identification; P=price transparency R=real comparisons; I=information on value; C=connect to care; E=ease of use