# List of Web Sites Reviewed

# | Web Sites | Sources | Decision
1. | http://64.64.16.103/wp-content/uploads/2012/09/hospital-cost-report-january-2011-final.pdf | IPI | Excluded
2. | http://adph.org/hai/ | RWJF | Excluded
3. | http://afh.org/ | Mathematica | Excluded
4. | http://ahq.ipro.org/ | RWJF | Excluded
5. | http://betterhealthcleveland.org/ | Mathematica | Excluded
6. | http://c354183.r83.cf1.rackcdn.com/MHQP%20Consumer%20Reports%20Insert%202012.pdf | RWJF | Excluded
7. | http://chia.unlv.edu/nevadahealthchoices/html/nevadahealthchoices.htm | RWJF | Excluded
8. | http://clearhealthcosts.com/ | IPI | Included
9. | http://communityhealthalliance.org/ | Mathematica | Excluded
10. | http://dhss.delaware.gov/dhss/dph/epi/dehospinfrpts.html | RWJF | Excluded
11. | http://epi.publichealth.nc.gov/cd/hai/figures.html | RWJF | Excluded
12. | http://forces4quality.org/alliance/greater-boston#twitter | Mathematica | Excluded
13. | http://gateway.maine.gov/MHDO/healthcost/ | RWJF, IPI | Included
14. | http://gateway.maine.gov/mhdo/monahrq/index.html | RWJF | Included
15. | http://gis.oshpd.ca.gov/atlas/ | RWJF, Mathematica | Included
16. | http://hcqcc.hcf.state.ma.us/ | RWJF, Mathematica | Included
17. | http://health.mo.gov/data/hai/drive_noso.php | RWJF | Excluded
18. | http://health.state.tn.us/Ceds/HAI/index.htm | RWJF | Excluded
19. | http://health.state.tn.us/statistics/specialprojects.htm#hdds | Journal | Excluded
20. | http://health.utah.gov/hda/report/inpatient.php | RWJF | Included
21. | http://healthcarequalitymatters.org/?p=fqc | RWJF | Included
22. | http://healthinsight.org/rankings/hospitals | RWJF, Mathematica | Excluded
23. | http://hospitals.nyhealth.gov/ | RWJF | Excluded
24. | http://iha.ncqa.org/reportcard/ | RWJF | Excluded
25. | http://info.kyha.com/QualityData/ | RWJF | Excluded
26. | http://mhcc.maryland.gov/consumerinfo/hospitalguide/hospital_guide/cost_report.html | RWJF | Excluded
27. | http://mhcc.maryland.gov/consumerinfo/hospitalguide/hospital_guide/reports/facility_comparison/index.asp?currentStatus=H | RWJF | Excluded
28. | http://mhcc.maryland.gov/consumerinfo/hospitalguide/hospital_guide/reports/healthcare_associated_infections/index.asp?currentStatus=H | RWJF, Mathematica, IPI | Excluded
29. | http://mncm.org/reports-and-websites/reports-and-data/ | RWJF, Mathematica | Excluded
30. | http://mnhealthactiongroup.org/ | Mathematica | Excluded
31. | http://morxcompare.mo.gov/ | Journal | Excluded
32. | http://mycarecompare.org/ | Mathematica | Included
33. | http://myvbch.org/about-vbch/services/report-cards/ | RWJF | Excluded
34. | http://nevadacomparecare.net/ | RWJF | Excluded
35. | http://nhhealthcost.usnh.edu/ | Journal | Included
36. | http://nmhealth.org/HAI/plans_reports.shtml | RWJF | Excluded
37. | http://nvpricepoint.net/ | RWJF | Included
38. | http://ohiohospitalcompare.ohio.gov/ | RWJF | Included
39. | http://oregonpatientsafety.org/reporting-programs/ | RWJF | Excluded
40. | http://p2quality.com/hospitalReporting.php | RWJF | Excluded
41. | http://provider.bcbs.com/#tab-1-content | RWJF | Excluded
42. | http://pub.azdhs.gov/hospital-discharge-stats/2011/index.html | RWJF | Included
43. | http://public.hcsc.net/providerfinder/home.do?corpEntCd=NM1 | IPI | Excluded
44. | http://public.health.oregon.gov/DiseasesConditions/CommunicableDisease/HAI/Pages/index.aspx | RWJF | Excluded
45. | http://publicapps.odh.ohio.gov/facilityinformation/ | RWJF, Mathematica | Excluded
46. | http://recognition.ncqa.org/ | RWJF | Excluded
47. | http://reportcard.opa.ca.gov/rc2013/ | RWJF | Excluded
48. | http://reportcard.opa.ca.gov/rc2013/medicalgroupcounty.aspx | RWJF | Excluded
49. | http://rx4excellence.org/getInformed/performanceMeasures/index.php | RWJF | Excluded
50. | http://the-collaborative.org/ | Mathematica | Excluded
51. | http://tnhospitalsinform.com/ | IPI | Excluded
52. | http://utahhealthscape.org/ | RWJF | Excluded
53. | http://utpricepoint.org/ | RWJF, IPI | Included
54. | http://web.doh.state.nj.us/apps2/hpr/ | RWJF, Mathematica | Excluded
55. | http://whynotthebest.org/ | RWJF | Included
56. | http://www.abouthealthsatisfaction.org/ | RWJF | Excluded
57. | http://www.abqhealthcarequality.org/ | RWJF | Excluded
58. | http://www.aetna.com/docfind/home.do | Journal | Excluded
59. | http://www.ahd.com/freesearch.php | RWJF | Included
60. | http://www.aligning4healthpa.org/ | RWJF, Mathematica | Included
61. | http://www.aligningforceshumboldt.org/find_quality_care.php | RWJF | Included
62. | http://www.anthem.com/wps/portal/ahpmember?content_path=shared/va/f1/s0/t0/pw_ad087638.htm&state=va&rootLevel=0&label=Performance%20report%20catalog | RWJF | Excluded
63. | http://www.azdhs.gov/plan/crr/cr/hospitals.htm#CostComparison | RWJF, IPI | Included
64. | http://www.bcbst.com/tools/hospital-quality/service.do | RWJF | Excluded
65. | http://www.betterhealthcleveland.org/Community-Health-Checkup.aspx | RWJF | Excluded
66. | http://www.calhospitalcompare.org/?v=2 | RWJF, Mathematica, journal | Excluded
67. | http://www.carechex.com/Default.aspx | RWJF | Excluded
68. | http://www.cbghealth.org/cbgh/?LinkServID=E1A62B2B-C267-A10F-ABAECC91AD53EA8A&showMeta=0 | RWJF | Excluded
69. | http://www.cchri.org/reports/physician_organizations.html | RWJF, Mathematica | Excluded
70. | http://www.cdph.ca.gov/programs/hai/Pages/HealthcareAssociatedInfections.aspx | RWJF | Excluded
71. | http://www.centralindianaallianceforhealth.org/reports/ | RWJF | Excluded
72. | http://www.cha.com/CHA/Resources/Colorado_Hospital_Report_Card/CHA/_Resources/Colorado_Hospital_Report_Card.aspx?hkey=a513e409-4b71-4eee-bbf6-1440067be285 | Mathematica | Excluded
73. | http://www.cha.com/pdfs/Discharge_Data/2010ChgRptnop.pdf | RWJF | Excluded
74. | http://www.chaboard.com/prices/index.html | IPI | Excluded
75. | http://www.chd.dphe.state.co.us/topics.aspx?q=Health_Facility_Acquired_Infections | RWJF | Excluded
76. | http://www.checkbook.org/patientcentral/?cb=cbgh | RWJF | Excluded
77. | http://www.chiaunlv.com/Reports/HealthChoices.php | IPI | Included
78. | http://www.cigna.com/web/public/hcpdirectory/ | RWJF | Excluded
79. | http://www.cimronebraska.org/Home/datamaps/nedata.aspx | RWJF | Excluded
80. | http://www.coap.org/for-the-public | RWJF | Excluded
81. | http://www.cohospitalprices.org/hprices/index.php | RWJF, IPI | Included
82. | http://www.cohospitalquality.org/ | RWJF | Excluded
83. | http://www.coloradohealthonline.org/cbgh/?LinkServID=6AEFBCC8-9D88-398C-72AE3FB8ECF47B50&showMeta=0 | RWJF, Mathematica | Excluded
84. | http://www.comparecarewv.gov/ | IPI | Excluded
85. | http://www.comparecarewv.gov/index.aspx | RWJF | Included
86. | http://www.ct.gov/dph/cwp/view.asp?a=3132&q=388090 | RWJF | Excluded
87. | http://www.cthosp.org/advocacy/quality-and-patient-safety/hospital-quality-reporting-website/ | RWJF | Excluded
88. | http://www.dads.state.tx.us/ | Mathematica | Excluded
89. | http://www.dartmouthatlas.org/ | RWJF, Mathematica | Excluded
90. | http://www.dfr.vermont.gov/ | RWJF, Mathematica, IPI | Included
91. | http://www.dhhs.nh.gov/dphs/cdcs/hai/documents/hai2011.pdf | RWJF | Excluded
92. | http://www.drscore.com/ | Mathematica | Excluded
93. | http://www.dshs.state.tx.us/thcic/ | RWJF, Mathematica | Excluded
94. | http://www.ehpco.com/consumer_guide.html
95. | http://www.floridahealthfinder.gov/CompareCare/SelectChoice.aspx | RWJF, Mathematica | Included
96. | http://www.floridahealthfinder.gov/LandingPages/NursingHomeGuide.aspx | RWJF, Mathematica | Included
97. | http://www.gdaha.org/resource-center/gdaha-publications | RWJF | Excluded
98. | http://www.getbettermaine.org/ | RWJF, Mathematica | Excluded
99. | http://www.hci3.org/ | RWJF, Mathematica | Excluded
100. | http://www.health.ny.gov/statistics/facilities/hospital/hospital_acquired_infections/ | RWJF | Excluded
101. | http://www.health.ri.gov/data/hospitalcareoutcomes/index.php | RWJF, Mathematica | Excluded
102. | http://www.health.ri.gov/publications/generalassemblyreports/2011HealthCareQualityPerformanceProgramAnnualReport.pdf | RWJF, Mathematica | Excluded
103. | http://www.health.ri.gov/publications/qualityreports/hospitals/PatientSatisfactionResults.pdf | RWJF, Mathematica | Excluded
104. | http://www.health.state.mn.us/healthreform/measurement/report/index.html#one | RWJF | Excluded
105. | http://www.health.state.mn.us/patientsafety/adverseselect.cfm | RWJF | Excluded
106. | http://www.health.state.ny.us/statistics/diseases/cardiovascular/ | RWJF | Excluded
107. | http://www.health.state.ok.us/stats/index.shtml | RWJF | Excluded
108. | http://www.health.utah.gov/epi/HAI/CLABSIdata.html | RWJF | Excluded
109. | http://www.healthcarereportcard.illinois.gov/ | RWJF, Mathematica | Included
110. | http://www.healthfinderla.gov/CQHospitals.aspx | RWJF | Excluded
111. | http://www.healthgrades.com/ | RWJF, Mathematica | Excluded
112. | http://www.healthpartners.com/portal/145.html | | Excluded
113. | http://www.healthymemphis.org/ | Mathematica | Excluded
114. | http://www.heart.org/HEARTORG/HealthcareResearch/GetWithTheGuidelinesHFStroke/GetWithTheGuidelinesHeartFailureHomePage/Recognition-from-Get-With-The-Guidelines-Heart-Failure_UCM_307818_Article.jsp | RWJF | Excluded
115. | http://www.heart.org/HEARTORG/HealthcareResearch/GetWithTheGuidelinesHFStroke/GetWithTheGuidelinesStrokeHomePage/Recognition-from-Get-With-The-Guidelines-Stroke_UCM_308034_Article.jsp | RWJF | Excluded
116. | http://www.hhicpublicreports.org/ | RWJF | Excluded
117. | http://www.hospitalcompare.va.gov/apps/Compare/index.asp | RWJF | Excluded
118. | http://www.hospitalconsumerassist.com/search.htm | RWJF, Journal | Included
119. | http://www.hospitalsafetyscore.org/licensure-and-permissions | RWJF | Excluded
120. | http://www.iha.org/ | Mathematica | Excluded
121. | http://www.ihconline.org/aspx/publicreporting/iowareport.aspx | RWJF, Mathematica | Excluded
122. | http://www.ihie.org/public-reporting | RWJF | Excluded
123. | http://www.in.gov/isdh/23433.htm | RWJF | Excluded
124. | http://www.in.gov/isdh/reports/QAMIS/hosrpt/index.htm | RWJF | Excluded
125. | http://www.iowahospitalcharges.com/ | RWJF, Journal, IPI | Included
126. | http://www.kaiserhealthnews.org/Stories/2012/April/18/community-health-center-chart.aspx | RWJF | Excluded
127. | http://www.kcqic.org/ | Mathematica | Excluded
128. | http://www.lahealthinform.org/ | RWJF | Included
129. | http://www.leapfroggroup.org/ | RWJF, Mathematica | Excluded
130. | http://www.lhcqf.org/ | Mathematica | Excluded
131. | http://www.ltcohio.org/consumer/index.asp | Mathematica | Excluded
132. | http://www.maine.gov/dhhs/mecdc/infectious-disease/hai/reports.shtml | RWJF | Excluded
133. | http://www.mass.gov/eohhs/gov/departments/dph/programs/hcq/healthcare-quality/health-care-facilities/hospitals/healthcare-assoc-infections/healthcare-associated-infections-reports.html | RWJF | Excluded
134. | http://www.medicare.gov/hospitalcompare/search.html | RWJF | Excluded
135. | http://www.medicare.gov/nursinghomecompare/search.html | Mathematica | Excluded
136. | http://www.mehmc.org/member-resources/publications/advanced-primary-care/ | RWJF | Excluded
137. | http://www.mhakeystonecenter.org/compare.htm | RWJF | Included
138. | http://www.mhaonline.org/quality/quality-performance-measures/quality-performance-measures | RWJF | Excluded
139. | http://www.mhqp.org/quality/whatisquality.asp?nav=030000 | RWJF, Mathematica | Excluded
140. | http://www.michigandrugprices.com/ | Journal | Excluded
141. | http://www.mihealthandsafety.org/2006_consumer/index.html | RWJF, Mathematica | Excluded
142. | http://www.missourihealthmatters.com/hospital-quality/ | RWJF | Excluded
143. | http://www.mnhealthscores.org/ | RWJF | Included
144. | http://www.mnhospitalpricecheck.org/ | RWJF | Included
145. | http://www.mnhospitalquality.org/ | RWJF | Excluded
146. | http://www.montanapricepoint.org/ | RWJF, Mathematica IPI, | Included
147. | http://www.mqf-online.com/summary/map.aspx | RWJF | Excluded
148. | http://www.mvphealthcare.com/provider/provider-metrics-2010.html | RWJF | Excluded
149. | http://www.mycarecompare.org/ | RWJF | Excluded
150. | http://www.myfloridarx.com/ | Journal | Excluded
151. | http://www.myhealthfinder.com/ | RWJF | Excluded
152. | http://www.myschospital.org/reports_step1.aspx | RWJF | Excluded
153. | http://www.nchospitalquality.org/ | RWJF | Excluded
154. | http://www.ncqa.org/tabid/631/default.aspx | Mathematica | Excluded
155. | http://www.ndhealth.gov/hf/pubs/NursingFacilityCharges/2011.pdf | Journal | Included
156. | http://www.nerdwallet.com/ | KI | Excluded
157. | http://www.nevadacomparecare.net/ | Journal | Included
158. | http://www.nhacarecompare.com/ | RWJF, IPI | Included
159. | http://www.nhhealthcost.org/costByProcedure.aspx | RWJF, Mathematica, IPI | Excluded
160. | http://www.nhpghscorecard.org/disclaimer.cfm?redirect=hospitalratings | RWJF, Mathematica | Excluded
161. | http://www.nhqualitycare.org/ | RWJF | Excluded
162. | http://www.njhcqi.org/index.php/resource-center/reports/18-new-jersey-hospital-price-transparency-report.html | RWJF, IPI | Included
163. | http://www.njhospitalcarecompare.com/index.aspx | RWJF | Included
164. | http://www.njhospitalpricecompare.com/ | RWJF, IPI, Journal | Excluded
165. | http://www.nmhanet.org/ | Mathematica | Excluded
166. | http://www.nortonhealthcare.com/ | Mathematica | Excluded
167. | http://www.nursinghomeguide.org/NHG/nhg_txt_home.lasso | Mathematica | Excluded
168. | http://www.nvhospitalquality.net/ | RWJF | Excluded
169. | http://www.nyc.gov/html/hhc/infocus/html/home/performance_landing.shtml | RWJF | Excluded
170. | http://www.oahhs.org/patient-services/price-point.html | Journal | Excluded
171. | http://www.ok.gov/health/documents/08%20Hospital%20AR.pdf | RWJF | Excluded
172. | http://www.ok.gov/health/Protective_Health/Medical_Facilities_Service/Facility_Services_Division/Hospital_Annual_Report/ | RWJF | Excluded
173. | http://www.ok.gov/health/Protective_Health/Medical_Facilities_Service/Facility_Services_Division/Hospital_Annual_Report/ | RWJF | Excluded
174. | http://www.okhca.org/ | Mathematica | Excluded
175. | http://www.okhospitalpricing.org/Default.aspx | RWJF | Excluded
176. | http://www.okhospitalquality.org/reports_step1.aspx | RWJF | Excluded
177. | http://www.opa.ca.gov/Pages/Home.aspx | Mathematica | Excluded
178. | http://www.oregon.gov/OHA/OHPR/docs/HCAIAC/Reports/Dec2010_Report/Final_Report.pdf?ga=t | RWJF, Mathematica | Excluded
179. | http://www.oregon.gov/OHA/OHPR/RSCH/comparehospitalcosts.shtml | RWJF | Excluded
180. | http://www.oregon.gov/oha/OHPR/RSCH/docs/Hospital_Report/Hospital_Report_2011.pdf | RWJF | Excluded
181. | http://www.orhospitalquality.org/ | RWJF | Excluded
182. | http://www.orpricepoint.org/ | RWJF | Included
183. | http://www.oshpd.ca.gov/Chargemaster/ | RWJF | Included
184. | http://www.oshpd.ca.gov/commonsurgery/Default.aspx | RWJF, IPI | Excluded
185. | http://www.oshpd.ca.gov/HID/DataFlow/HospQuality.html | RWJF | Excluded
186. | http://www.oshpd.ca.gov/HID/Products/Clinical_Data/CABG/10Breakdown.html | RWJF | Excluded
187. | http://www.pacificmedicalcenters.org/index.php/about-us/quality-innovations/ | Mathematica | Excluded
188. | http://www.partnerforqualitycare.org/ | RWJF | Excluded
189. | http://www.patientcarelink.org/hospital-data/performance-measures.aspx | RWJF | Excluded
190. | http://www.patientchoicehealthcare.com/ins/PCInsights_HospGde_2011.pdf | RWJF | Included
191. | http://www.patientchoicesignature.com/aboutpcs/consumersurvey.html | RWJF | Excluded
192. | http://www.pbgh.org/ | Mathematica | Excluded
193. | http://www.pbghpa.com/ | Mathematica | Excluded
194. | http://www.phc4.org/hpr/ | RWJF, Mathematica | Included
195. | http://www.phc4.org/medicarepayments/Search.aspx | RWJF, Mathematica, IPI | Excluded
196. | http://www.phcqa.org/ | RWJF | Excluded
197. | http://www.portal.state.pa.us/portal/server.pt/community/healthcare_associated_infections/14234/hai_annual_reports/1403644 | RWJF | Excluded
198. | http://www.q-corp.org/ | Mathematica | Excluded
199. | http://www.qqhc.com/ | Mathematica | Excluded
200. | http://www.qualitycheck.org | RWJF, Mathematica | Excluded
201. | http://www.qualityhealthtogether.org/find_quality_care.php | RWJF | Excluded
202. | http://www.qualityquest.org/quality-reports/ | RWJF | Excluded
203. | http://www.rethinkhealthy.org/ | RWJF | Excluded
204. | http://www.rx4excellence.org/diabetesPhysicians/index.php | RWJF | Excluded
205. | http://www.savannahbusinessgroup.com/ | Mathematica | Excluded
206. | http://www.scbch.org/hospital-quality-guide/ | RWJF | Excluded
207. | http://www.scdhec.gov/health/disease/hai/individual_041612.htm | RWJF | Excluded
208. | http://www.sdhospitalquality.org/search.php | RWJF | Excluded
209. | http://www.sdpricepoint.org/ | RWJF, IPI | Included
210. | http://www.state.nj.us/health/healthcarequality/ | RWJF | Excluded
211. | http://www.stlbhc.org/healthcare.aspx | RWJF | Excluded
212. | http://www.stlbhc.org/healthcare.aspx | RWJF | Excluded
213. | http://www.sts.org/quality-research-patient-safety/sts-public-reporting-online | RWJF | Excluded
214. | http://www.tnhospitalsinform.com/reporting.aspx | RWJF | Included
215. | http://www.txpricepoint.org/consumer.aspx | RWJF | Included
216. | http://www.ucomparehealthcare.com/ | RWJF, Mathematica | Included
217. | http://www.uhc.com/find_a_physician.htm | RWJF, Mathematica | Excluded
218. | http://www.uhc.com/individuals_families/member_tools/myhealthcare_cost_estimator.htm | Journal | Excluded
219. | http://www.uhc.com/physicians/care_programs/unitedhealth_premium_designation.htm | Journal | Excluded
220. | http://www.usnews.com/ | Mathematica | Excluded
221. | http://www.utcheckpoint.org/reports_step1.aspx | RWJF | Excluded
222. | http://www.va.gov/HEALTH/docs/2012_VHA_Facility_Quality_and_Safety_Report_FINAL508.pdf | RWJF | Excluded
223. | http://www.vapricepoint.org/ | RWJF | Included
224. | http://www.vhha.com/qualityscorecard.html | RWJF | Excluded
225. | http://www.vhi.org/healthcare.asp | RWJF, Mathematica | Included
226. | http://www.vhi.org/hospitals.asp | RWJF, Mathematica | Excluded
227. | http://www.vhi.org/outpatient_compare.asp | RWJF, Mathematica | Included
228. | http://www.vhi.org/physicians.asp | RWJF, Mathematica | Included
229. | http://www.vimo.com/hospital/browseprocedures.php | RWJF | Excluded
230. | http://www.vitals.com/ | Journal | Excluded
231. | http://www.wacommunitycheckup.org/?p=viewreports&orgname=all&county=All+Counties | RWJF, Mathematica | Excluded
232. | http://www.wahospitalpricing.org/ | RWJF | Included
233. | http://www.wahospitalquality.org/ | RWJF | Excluded
234. | http://www.wbchc.com/resources/resources.htm | RWJF, Mathematica | Excluded
235. | http://www.wchq.org/reporting/ | RWJF, Mathematica | Excluded
236. | http://www.whainfocenter.com/data_resources/2010_hcdr.htm | RWJF | Included
237. | http://www.whainfocenter.com/data_resources/2011WIInpatientQIRelease.pdf | RWJF | Excluded
238. | http://www.wheretofindcare.com/default.aspx | RWJF | Excluded
239. | http://www.wicheckpoint.org/reports_step1.aspx | RWJF | Excluded
240. | http://www.wipricepoint.org/ | RWJF, IPI | Included
241. | http://www.wisconsinhealthreports.org/data | RWJF | Excluded
242. | http://www4.cbs.state.or.us/ex/ins/hit/ | IPI | Excluded
243. | http://wyopricepoint.com/ | RWJF, IPI | Included
244. | http://yourhealthmatters.org/ | RWJF | Excluded
245. | https://findadoctor.bluecrossma.com/ | RWJF | Excluded
246. | https://health.data.ny.gov/Health/Hospital-Inpatient-Cost-Transparency-Beginning-200/7dtz-qxmr | IPI | Included
247. | https://health.utah.gov/myhealthcare/ | RWJF, Mathematica | Included
248. | https://health.utah.gov/myhealthcare/hospital.htm | RWJF, Mathematica | Included
249. | https://health.utah.gov/myhealthcare/monahrq/index.html | Journal | Excluded
250. | https://health.utah.gov/myhealthcare/reports/hcahps/index.php?doc=2&mytabsmenu=3 | RWJF | Excluded
251. | https://info.kyha.com/Pricing/MSDRG/SelectHospital.asp | RWJF | Included
252. | https://ltc.dph.illinois.gov/webapp/LTCApp/ltc.jsp | Journal | Included
253. | https://prd.chfs.ky.gov/MONAHRQ/2011/ | RWJF, Journals | Excluded
254. | https://www.anthem.com/health-insurance/provider-directory/searchcriteria?qs=*bnlC7RuslFfU3qxduSJdoQ==&brand=abcbs | Journal | Excluded
255. | https://www.bcbsal.org/web/index.html | RWJF | Excluded
256. | https://www.bcbsri.com/about-us/improving-healthcare-delivery/hospital-quality-program | RWJF | Excluded
257. | https://www.blueshieldca.com/fap/app/search.html | RWJF | Excluded
258. | https://www.geoaccess.com/uhc/po/Default.asp | RWJF | Excluded
259. | https://www.harvardpilgrim.org/portal/page?_pageid=213,233601&_dad=portal&_schema=PORTAL | RWJF, Mathematica | Excluded
260. | https://www.health.ny.gov/ | Mathematica | Excluded
261. | https://www.healthcarebluebook.com/ | IPI | Excluded
262. | https://www.healthnet.com/portal/member/prvfinder/searchMedicalGroupsForm.do?category=DoctorSearch&topic=CompareMedicalGroups&region=CA | RWJF | Excluded
263. | https://www.medica.com/members#quality | RWJF | Excluded
264. | https://www.ncha.org/issues/finance/top-35-drgs | IPI | Included
265. | https://www.ncha.org/issues/finance/top-35-drgs | RWJF | Excluded
266. | https://www.phin.state.ok.us/ahrq/MONAHRQ%202010/index.html | RWJF | Excluded
267. | https://www.providerlookuponline.com/harvardpilgrim/po7/Search.aspx | RWJF | Excluded
268. | https://www.uhcwest.com/vgn/images/portal/cit_60701/600715339_PCA140967_004.pdf | RWJF, Mathematica | Excluded
269. | https://www.uhcwest.com/vgn/images/portal/cit_60701/600762581_PCA080402_009.pdf | RWJF, Mathematica | Excluded
270. | https://www6.state.nj.us/LPSCA_DRUG/index.jsp | Journal | Excluded

RWJF=Robert Wood Johnson Foundation, IPI=Informed Patient Institute