# Targeted Literature Review

A targeted review is a type of narrative review that includes a synthesis of both qualitative and quantitative research on cost reporting. This differs from the Web site review described elsewhere in this technical brief. We included key articles identified by experts as well as those identified from a search of electronic databases of published literature.1-3 We used the literature review to alert us to public Web sites reporting cost data (GQ 1), and to clarify definitions and criteria to assess the consumer centeredness of these Web sites (GQ 2).

We developed a search strategy for MEDLINE, accessed via PubMed^®^, based on an analysis of the medical subject headings terms and text words of relevant articles (Box A1). We translated this strategy and used it for the other electronic sources. We searched the following databases for primary studies published from 2009 to 2013: MEDLINE^®^, EconLit, and Scopus.

Box A1 Search string

PubMed ((“public report” [tiab] OR “public reports”[tiab] OR “cost report”[tiab] OR “cost reports”[tiab] OR “report card”[tiab] OR “report cards”[tiab] OR “provider profiling”[tiab] OR “provider profile”[tiab] OR “provider profiles”[tiab]OR “score card”[tiab] OR “score cards”[tiab] OR “cost transparency”[tiab] OR “price transparency”[tiab] OR “pay for performance”[tiab] OR “public performance reports”[tiab] OR “consumer report”[tiab] OR “consumer reports”[tiab])) AND ((cost[mh] OR cost[tiab] OR charge[tiab] OR price[tiab] or utilization[tiab] OR spending[tiab] OR efficiency[tiab])) Filters: Publication date from 2009/01/01 to 2013/12/31; English
Scopus (((TITLE-ABS-KEY(“public report”) OR TITLE-ABS-KEY(“public reports”) OR TITLE-ABS-KEY(“cost report”) OR TITLE-ABS-KEY(“cost reports”) OR TITLE-ABS-KEY(“report cards”) OR TITLE-ABS-KEY(“report card”) OR TITLE-ABS-KEY(“provider profiling”) OR TITLE-ABS-KEY(“provider profile”) OR TITLE-ABS-KEY(“provider profiles”) OR TITLE-ABS-KEY(“score card”) OR TITLE-ABS-KEY(“score cards”) OR TITLE-ABS-KEY(“cost transparency”) OR TITLE-ABS-KEY(“price transparency”) OR TITLE-ABS-KEY(“pay for performance”) OR TITLE-ABS-KEY(“public performance reports”) OR TITLE-ABS-KEY(“consumer report”) OR TITLE-ABS-KEY(“consumer reports”))) AND ((TITLE-ABS-KEY(cost) OR TITLE-ABS-KEY(charge) OR TITLE-ABS-KEY(price) OR TITLE-ABS-KEY(utilization) OR TITLE-ABS-KEY(spending) OR TITLE-ABS-KEY(efficiency)))) AND (TITLE-ABS-KEY(“health care”) OR TITLE-ABS-KEY(“healthcare”)) AND (LIMIT-TO(LANGUAGE, “English”)) AND (LIMIT-TO(PUBYEAR, 2013) OR LIMIT-TO(PUBYEAR, 2012) OR LIMIT-TO(PUBYEAR, 2011) OR LIMIT-TO(PUBYEAR, 2010) OR LIMIT-TO(PUBYEAR, 2009))
Econlit ( TX “public report” OR TX “public reports” OR TX“cost report” OR TX “cost reports” OR TX “report card” OR TX “report cards” OR TX “provider profiling” OR TX “provider profile” OR TX “provider profiles” OR TX “score card” OR TX “score cards” OR TX “cost transparency” OR TX “price transparency” OR TX “pay for performance” OR TX “public performance reports” OR TX “consumer report” OR TX “consumer reports” ) AND ( TX cost OR TX charge OR TX price OR TX utilization OR TX spending OR TX efficiency ) AND ( TX “healthcare” OR TX “ health care” ) Limiters - Published Date: 20090101-20131231

Given that public reporting is a relatively new phenomenon, and that we focused on current reporting practices, we required that articles be published after 2009, address public reporting of costs in U.S. health care, and inform one or both of the GQs. Four trained reviewers independently screened articles at the title and abstract level. We paired reviewers. If both reviewers agreed that an article met one or more of the exclusion criteria, we excluded it (Table A1). For all citations that we promoted on the basis of title and abstract, paired reviewers also conducted a second independent review of the full text of the articles.

Table A1 Inclusion and exclusion criteria for the targeted literature review

Review Stage | Include | Exclude
Title/Abstract level | ✓ Study published after 2009; ✓ Public reports of cost data in health care in the United States | - No mention of health care cost data; - No mention of public reporting; - Not in English; - Study conducted outside of the United States
Full article level | ✓ Public reports of cost data in health care in the United States; ✓ Address one or more guiding Questions | - No mention of health care cost data; - No mention of public report; - Not in English; - Study conducted outside of the United States

At least two reviewers read the included articles in full (ZB and TK or NN) and summarized the information from articles that answered the two GQs. The intent was to present a summary of the approaches which illuminate the GQs. The methods we used are consistent with generally recognized standards for the conduct of narrative reviews, which are: provide a balanced overview, summarize the main findings of the most important contributions to the literature, make references to supporting theory and assumptions, and provide support for further quantitative review. We summarized key information in tables and described them in the narrative.

The database search yielded 974 titles, supplemented by 54 titles in the hand search. Of these, 786 titles advanced to the title/abstract review stage, and 154 advanced to the full-text screening. We retained 32 articles for the targeted review. Twenty-one of these articles addressed measures of costs that have been publicly reported (GQ 1) and 23 addressed the consumer centeredness of the measures of cost (GQ 2). For full details of inclusion and exclusion, see Figure A1.

Figure A1 Summary of targeted literature review

* Total exceeds the number of citations in the exclusion box, because citations could be excluded for more than one reason

¥ Other reasons for exclusion at title-abstract screening phase: no focus on consumers or healthcare, no individual provider level data, pharma related article

¶ Other reasons for exclusion at full-text screening phase: health policy review, book review, not relevant to research questions, no focus on consumers

Figure A1: The figure shows the targeted literature search via a vertical search flow diagram. The first box shows the Electronic databases that were searched, MEDLINE, EconLit and Scopus, and how many returns from the search with a box to right showing the articles retrieved through handsearch. The next box has total retrieved titles. Then there is a box to the right has number of duplicate citations, then title-abstract review, then a box to the right with excluded titles, then below, article review, with a box to the right with excluded articles and another box to the right with reasons for exclusion at article review level. Finally, there is a box with the final number of the included studies.

Table A2 Included articles for the targeted literature review by guiding questions

Author, Year | Journal or Publication Names | Type of Article | GQ 1^*^ | GQ 2^**^
Adamopoulos, 2013 | Becker's Hospital Review | News | | X
Aligning Forces for quality, 2011 | Robert Wood Johnson Foundation | Organizational report | X | X
Aligning Forces for quality, 2012 | Robert Wood Johnson Foundation | Organizational report | X | X
Bardach , 2011 | Agency for Healthcare Research and Quality | Original Research | X | X
Barlas, 2010 | Pharmacy and Therapeutics Community | Original Research | | X
Catalyst for payment reform, 2012 | Catalyst for payment reform | Organizational report | | X
Christianson, 2010 | Journal of General Internal Medicine | Original Research | X | X
Dudley, 2011 | Agency for Healthcare Research and Quality | Original Research | X | X
Hibbard, 2012 | Health Affairs | Original Research | | X
James, 2012 | Health Affairs | Commentary | X | X
Kaiser health news, 2010 | Kaiser Health News | News | | X
Kullgren, 2013 | Journal of the American Medical Association | Original Research | X
Luft, 2012 | Health Affairs | Commentary | X | X
Mehrotra, 2010 | Annals of Internal Medicine | Original Research | X
Mehrotra, 2012 | Health Affairs | Original Research | | X
NCSL, 2013 | National conference of state legislatures | Organizational report | X
NYTimes.com, 2012 | New York Times | News | X | X
O'Neil, 2010 | Mathematica Policy Research | Original Research | X
Park, 2011 | Health Services Research | Original Research | X
Reinhardt, 2013 | Journal of the American Medical Association | Commentary | | X
Report to congressional requesters, 2011 | Report | Governmental report | X | X
Robinson, 2013 | Health Affairs | Original Research | X
Sick, 2011 | American Journal of Medical Quality | Original Research | X | X
Sinaiko, 2011 | The New England Journal of Medicine | Commentary | X
Sinaiko, 2011 | Health Services Research | Original Research | | X
Sinaiko, 2012 | Health Affairs | Original Research | | X
Sofaer, 2011 | School of Public Affairs, Baruch College | Commentary | | X
Swartz, 2010 | Robert Wood Johnson Foundation | Organizational report | X | X
Tu, 2009 | Issue Brief Center for the Study Health System Change | Organizational report | X | X
Wall, 2013 | Indianapolis Business Journal | News | X
Yegian, 2013 | Health Affairs | Original Research | | X
Young, 2012 | Health Affairs | Original Research | X

* GQ 1: What measures of costs about health care providers have been publicly reported?

** GQ 2: Are the cost measures reported in a consumer-centered way?

## Appendix A References

Adamopoulos. 10 Characteristics of Effective Healthcare Price Transparency Tools. 2013. Available at http://www.beckershospitalreview.com/racs-/-icd-9-/-icd-10/10-characteristics-of-effective-healthcare-price-transparency-tools.html.
Aligning Forces for quality. Consumer Beliefs and Use of Information about Health Care Cost Resource Use, and Value Findings from Consumer Focus Groups. 2012.
Aligning Forces for quality. Primer/Brief : Public Reporting of Cost & Resource Use Measures to Consumers. 2011.
Bardach NS, Hibbard JH, Dudley RA. Users of Public Reports of Hospital Quality: Who, What, Why, and How?: An aggregate analysis of 16 online public reporting Web sites and users' and experts' suggestions for improvement. Rockville, MD. Agency for Healthcare Research and Quality. 2011. Publication No. 12-0016-EF.
Barlas S. The Unfinished Business Of Health Care Reform: Congress Turns to Medical Price Transparency. Pharmacy and Therapeutics. 2010;35(7):369-372.
Catalyst for payment reform. Comprehensive Specifications for the Evaluation of Transparency Tools. Available at http://www.catalyzepaymentreform.org/images/documents/Price_Transparency_Specifications.pdf.
Christianson JB, Volmar KM, Alexander J, Scanlon DP. A report card on provider report cards: current status of the health care transparency movement. J Gen Intern Med. Nov. 2010;25(11):1235-41. [pmid: 20625849].
Dudley RA, Hibbard JH, Shaller D, Sofaer S. Model Public Report Elements: A Sampler. Rockville, MD. Agency for Healthcare Research and Quality. 2010. AHRQ Publication No. 10-0088.
Hibbard JH, Greene J, Sofaer S, Firminger K, Hirsh J. An experiment shows that a well-designed report on costs and quality can help consumers choose high-value health care. Health Aff (Millwood). Mar. 2012;31(3):560-8. [pmid: 22392666].
James J. Health Policy Brief: Public Reporting on Quality and Costs. Do report cards and other measures of providers' performance lead to improved care and better choices by consumers?. Health Affairs. March. 08. 2012.
Kaiser Health News. Employers, unions ask for greater health care price transparency. http://www.kaiserhealthnews.org/Daily-Reports/2012/November/01/transparency-and-coverage.aspx.
Kullgren JT, Duey KA, Werner RM. A census of state health care price transparency Web sites. JAMA. Jun. 19. 2013;309(23):2437-8. [pmid: 23780454].
Luft HS. Advancing public reporting through a new ‘aggregator’ to standardize data collection on providers' cost and quality. Health Aff (Millwood). Mar. 2012;31(3):619-26. [pmid: 22392674].
Mehrotra A, Adams JL, Thomas JW, McGlynn EA. The effect of different attribution rules on individual physician cost profiles. Ann Intern Med. May. 18. 2010;152(10):649-54. [pmid: 20479030].
Mehrotra A, Hussey PS, Milstein A, Hibbard JH. Consumers' and providers' responses to public cost reports, and how to raise the likelihood of achieving desired results. Health Aff (Millwood). Apr. 2012;31(4):843-51. [pmid: 22459922].
National Conference of State Legislatures. State and federal actions related to transparency and disclosure of health charges and provider payments. Available at http://www.ncsl.org/issues-research/health/transparency-and-disclosure-health-costs.aspx.
O'Neil S, Schurrer J, Simon S. Environmental scan of public reporting programs and analysis: final report: Mathematica Policy Research report submitted to the National Quality Forum. Washington (DC). National Quality Forum. 2010. Sep. 30.
Park J, Konetzka RT, Werner RM. Performing well on nursing home report cards: does it pay off?. Health Serv Res. Apr. 2011;46(2):531-54. [pmid: 21029093].
Reinhardt UE. The disruptive innovation of price transparency in health care. JAMA. Nov. 13. 2013;310(18):1927-8. PubMed PMID. [pmid: 24219941].
Report to congressional requester. 2011. Health Care Price Transparency Meaningful Price Information is Difficult for Consumer to Obtain to receiving care.
Robinson JC, Brown TT. Increases in consumer cost sharing redirect patient volumes and reduce hospital prices for orthopedic surgery. Health Aff (Millwood). Aug. 2013;32(8):1392-7. [pmid: 23918483].
Sick B, Abraham JM. Seek and ye shall find: consumer search for objective health care cost and quality information. Am J Med Qual. 2011.
Sinaiko AD, Eastman D, Rosenthal MB. How report cards on physicians, physician groups, and hospitals can have greater impact on consumer choices. Health Aff (Millwood). Mar. 2012;31(3):602-11. [pmid: 22392672].
Sinaiko AD, Rosenthal MB. Increased price transparency in health care--challenges and potential effects. N Engl J Med. Mar. 10. 2011;364(10):891-4. [pmid: 21388306].
Sinaiko AD. How do quality information and cost affect patient choice of provider in a tiered network setting? Results from a survey. Health Serv Res. Apr. 2011;46(2):437-56. [pmid: 21143478].
Sofaer S. Engaging consumers with a high value healthcare system: public reporting of cost and resource use. Presentation at: Aligning Forces for Quality National Meeting. 2011 May. Denver, CO.
Swartz K. Cost-sharing: effects on spending and outcomes. Synth Proj Res Synth Rep. Dec. 2010;(20). [pii: 71583]. [pmid: 22052221].
The Confusion of Hospital Pricing. New York Times. Available at http://well.blogs.nytimes.com/2012/04/23/the-confusion-of-hospital-pricing/?_r=0.
Tu HT, Lauer JR. Impact of health care price transparency on price variation: the New Hampshire experience. Issue Brief Cent Stud Health Syst Change. Nov. 2009;(128):1-4. [pmid: 19908405].
Wall JK. WellPoint rolls out program with cost ceilings for procedures. Available at http://www.ibj.com/articles/42450-wellpoint-rolls-out-program-with-cost ceilings-for-procedures.
Yegian JM, Dardess P, Shannon M, Carman KL. Engaged patients will need comparative physician-level quality data and information about their out-of-pocket costs. Health Aff (Millwood). Feb. 2013;32(2):328-37. [pmid: 23381526].
Young GJ. Multi stakeholder regional collaboratives have been key drivers of public reporting, but now face challenges. Health Aff (Millwood). Mar. 2012;31(3):578-84. [pmid: 22392669].