# Summary and Implications

Monitoring how well quality care is delivered to those with a serious mental illness (SMI), who are some of the most vulnerable Americans served by the Affordable Care Act, is crucial. It is also a great challenge. We have attempted to describe the current state of the art regarding the use of quality measures (QMs) in the seriously mentally ill and to describe the evidence supporting their use. We note that the challenges of QM research are not limited to measurement in the SMI population, but extend to QM measurement in general.86 For example, in cardiovascular disease, the utility of QMs for improving patient outcomes remains unclear.87 While measuring quality may improve quality for processes of care, their use has not been shown to improve outcomes; unless these process measures are closely tied to outcomes that individuals directly face as a patient, such as mortality, hospital readmission, or the patient experience, their impact remains quite uncertain.87 Further, the use of QMs in non-SMI medical populations may have unintended consequences, including inappropriate clinical care, distracting providers from patient concerns, and negative effects on patient education and autonomy.66,67

With these caveats, we identify a number of key issues below that we believe affect QM measurement in SMI populations.

A key issue is to determine what strength of evidence base is necessary to support implementation of QMs. Key Informants (KIs) and the literature were in agreement that an evidence base was an important piece of successful implementation, but KIs and the literature both reflected the great challenges inherent in conducting this line of research. KIs emphasized concern for whether such difficult and time-consuming research would get funded, which raises an important question: what strength or degree of evidence base is necessary to proceed with implementation of QMs that may have strong face validity, but limited evidence that using such QMs ultimately improves outcomes? Such a practical discussion is critical in an era of funding constraints.

A second key issue, and our most striking finding, is that no research has studied the association between QM use and improved processes of care or improved outcomes of care for the SMI population. The importance of this absence of evidence cannot be overstated. Evidence does not exist that indicates that certain processes or measures often used as proxies for quality of care actually measure quality of care or improve outcomes. Such evidence is necessary before poorly constructed QMs are put into place and physician care/performance is linked to them. This is a key issue for an initiative that intends to be evidence based, and the absence of such a base creates substantial barriers to implementation. Specifically, without such an evidence base, it is challenging to identify the most effective QMs to implement in specific situations.

An evidence base is absent for outcomes (the standards against which QMs are measured) as well as for the QMs themselves. For the former, the most meaningful psychiatric and patient-centered outcomes (those that reflect patients' ability to function and participate in their community) are very difficult to measure accurately; most outcomes measures instead reflect proxies (processes of care or fidelity to evidence-based guidelines), which themselves have an unclear relation to improved outcomes and do not generally incorporate patient-centered outcomes. Having these outcomes is necessary to assess the effectiveness of a QM. Without such clear and meaningful outcome standards, the effectiveness of QMs cannot be assessed. For the latter, the diversity of opinions on how to define and identify QMs and which ones are preferable to use complicates the decision about which QMs to test. As noted above, it is not clear that the QMs used in other medical conditions fare better than those used in SMI; indeed, links between QMs and outcomes in non-SMI conditions can be similarly thin.88,89

A third issue is considering when to invest the time and resources on measuring outcomes of care to evaluate the impact of QMs and when process measures (proxies of the outcomes) are a reasonable and more feasible alternative. Although KIs ultimately noted that outcomes are the most important measures, many KIs supported measuring processes rather than outcomes to prevent incentivizing providers to take on the easier cases. The literature was beginning to address how to adjust for case mix, but this remained a very strong concern. This tension over what QMs should measure hinders QM implementation and decisions about how to select the best QMs to use.

A fourth issue emphasizes that barriers to QM implementation were not limited to the absence of an evidence base, but also involve the need for resources to support such a substantial change in practice. Key resource barriers include limited time (e.g., any time to assess QMs took away from patient care) and the need for personnel, electronic health records, and training to implement and follow up on QMs (e.g., if a patient missed followup after psychiatric hospitalization, was the hospital or the outpatient provider responsible for making sure that the patient was seen in followup?). A practical consideration here is making sure that outcomes measured are comprehensive (i.e., they include service use that is provided across the different health care systems that a patient may access). KIs suggested that collaboration might lead to more cost-effective approaches to QM data collection monitoring and prevent scarce health care resources from being diverted from direct patient care. The literature and the KIs agree that better aligning payment with quality of care measures, rather than volume of services, is necessary to increase the likelihood of QM use. Such a shift would be a dramatic change and would likely require a substantial effort.

A fifth issue is for a QM to address the practical needs of the health care providers. For QMs to affect patient care, at least some had to show real-time use, be feasible, and provide actionable information. Clinicians need to see outcomes in real time so that they can immediately modify their interventions to address poor outcomes, consistent with a quality improvement cycle.

## Next Steps

Based on the literature review and interviews with Key Informants (KIs), we identified certain questions that need to be explored to improve the selection, implementation, and evidence base for the use of quality measures (QMs) in the seriously mentally ill.

### 1 What Strength of Evidence Base Linking QMs to Improved Outcomes Is Necessary To Support Implementation of QMs?

Currently no evidence base links QMs directly with improved outcomes, although stakeholders note the importance of having one. Practical considerations may play a key role here. Stakeholders believe that research assessing the evidence base for QMs often has a low likelihood of being funded, and they identified an important consideration to be whether the absence of a solid evidence base should preclude use of QMs that have strong face validity. Given the challenges of developing such an evidence base (both financial and temporal), stakeholders need a plan to test meaningful and measurable QMs as well as an understanding of whether/how to select and implement QMs in the absence of a clear evidence base.

#### Suggestions for Addressing This Question

A meeting with stakeholders can be used to design an action plan for obtaining the relevant evidence necessary to develop a useful evidence base. Discussions would include the need for randomized controlled trials versus other study designs (e.g., observational cohorts, use of secondary data analyses of large databases), how best to target the use of likely limited research funding, and evidence thresholds that need to be met before supporting the use of a QM. Essential areas to research include (1) assessing the impact of QMs on the process of care and whether the benefits outweigh the costs, (2) combining QMs with payment mechanisms for mental health care (i.e., understanding how QMs tie into greater cost efficiency), and (3) understanding how electronic medical records can be used to gauge the quality of a system. The design and implementation of a randomized controlled trial or a quasi-experimental study to test the effectiveness of a QM or set of QMs relative to a meaningful and feasible outcome would be an especially important step.

### 2 What Are the Most Important Outcomes With Which To Compare QMs?

This step is key to developing effective QMs. Stakeholders need to agree on meaningful, measurable, and actionable outcomes to set as standards. These outcomes will likely involve both outcomes and proxy outcomes, with stakeholders noting what constitutes a reasonable balance.

#### Suggestions for Addressing This Question

As with question #1, a meeting with broad participation from key stakeholder groups may be useful for reaching a general consensus on this issue. Ideally, these groups would include representatives from the National Committee for Quality Assurance, the National Quality Forum, and the Joint Commission. Input from both providers and patients is especially important.

### 3 How To Address Resource Barriers for QM Implementation?

Although the above questions emphasize the limited knowledge base as a barrier to implementation, the limited resource base to support implementation in real world clinic settings is a similarly important barrier. Indeed, the challenges of collecting QM data in ways that providers and organizations can use them; of analyzing the data; and of providing data-driven feedback to providers that allow a clinical response in real time may be as difficult as developing the evidence base. Key variables include personnel, electronic health records, and training on implementing and monitoring QMs.

#### Suggestions for Addressing This Question

Models that consider how to balance personnel needs, patient care needs, and financial demands need to be tested. The Department of Veteran Affairs system, which has addressed some of these barriers, might be able to provide useful guidance. The State of Maryland, in collaboration with the University of Maryland, has also been successful implementing the use of quality of care measures in real-world practice. Also, conducting research projects collaboratively designed by various stakeholders to help sort out these critical areas would help inform this issue.

### 4 What Is a Reasonable and Feasible Collection of QMs To Be Implemented, and How Might These Collections Be Tailored to Specific Settings and Purposes?

Much of this information would likely be guided by research findings referred to in question #2 above. Input from providers and patients, especially regarding feasibility and applicability to particular settings, would be especially useful here. Currently, providers have a large collection of potentially relevant QMs with little guidance to select which measures to use (beyond those requiring measures to obtain reimbursement).

#### Suggestions for Addressing This Question

As noted above, the developing evidence base plus input from those involved in implementation (patients, providers) would guide the development of this collection. Identification of a feasible and clinically useful inventory of QMs for a particular setting is critical.

### 5 How Best To Address the Conceptual Issues That Underlie the Role of QMs in the Care of the SMI Population?

Consideration of how QMs might be able to effectively improve clinical practices requires understanding the links between three areas—routine clinical practice; the identification, selection, and implementation of QMs (which is informed by routine clinical practice); and what change can be expected from implementing QMs (which is informed by both routine clinical practice and what QMs are implemented). Our review did not address the first area, which provides the layer of evidence to generate QMs. We found only qualitative information for the second area (Guiding Questions [GQs] 1 and 2). And we found no evidence addressing the third area (GQ 3).

#### Suggestions for Addressing This Question

The links between these three areas are unknown, and the evidence addressing these areas is missing. We recommend considering an expert panel that can think through a number of key conceptual issues to guide work in this area, to include addressing the following question: What are the conceptual relationships between routine clinical practice; identification, selection, and implementation of QMs; and expected change from implementation of QMs?