# References

1 The Patient Protection and Affordable Care Act (PPACA). 111th Congress Session, Public Law Number: 111-148, Statute Number:124 STAT. 119. Volume, pages. 2010.
2 Peck MC, Scheffler RM. An analysis of the definitions of mental illness used in state parity laws. Psychiatr Serv. Sep. 2002;53(9):1089-95. Epub: 2002/09/11. [pmid: 12221306].
3 Epstein J, Barker P, Vorburger M, et al. Serious mental illness and its co-occurrence with substance use disorders, 2002. Substance Abuse and Mental Health Services Administration. Office of Applied Studies. (DHHS Publication No. SMA 04-3905, Analytic Series A-24). Rockville, MD. 2004.
4 National Institute of Mental Health. Transforming the understanding and treatment of mental illnesses. Washington, DC. U.S. Department of Health and Human Services. www.nimh.nih.gov/health/statistics/prevalence/serious-mental-illness-smi-among-us-adults.shtml. September 24, 2014.
5 Substance Abuse and Mental Health Services Administration. Results from the 2008 National Survey on Drug Use and Health: National findings. Department of Health and Human Services. NSDUH Series H-36. HHS Publication No. SMA 09-4434. Rockville, MD. 2009.
6 Wang PS, Demler O, Kessler RC. Adequacy of treatment for serious mental illness in the United States. Am J Public Health. Jan. 2002;92(1):92-8. Epub: 2002/01/05. [pmid: 11772769].
7 Druss BG, Bornemann TH. Improving health and health care for persons with serious mental illness: The window for US federal policy change. JAMA. May. 19. 2010;303(19):1972-3. Epub: 2010/05/21. [pmid: 20483975].
8 Gierisch JM, Nieuwsma JA, Bradford DW, et al. Interventions to Improve Cardiovascular Risk Factors in People With Serious Mental Illness. Comparative Effectiveness Review No. 105. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-2007-10066-I.) AHRQ Publication No. 13-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2013.
9 Parks J, Svendsen D, Singer P, et al. Morbidity and Mortality in People with Serious Mental Illness. National Association of State Mental Health Program Directors, Medical Directors Council. 2006. www.nasmhpd.org/docs/publications/MDCdocs/Mortality%20and%20Morbidity%20Final%20Report%208.18.08.pdf. September 24, 2014.
10 Reeves WC, Strine TW, Pratt LA, et al. Mental illness surveillance among adults in the United States. MMWR Surveill Summ. Sep. 2. Suppl 3. 2011;60:1-29. Epub: 2011/09/09. [pmid: 21881550].
11 Verdier M, Bagchi AD, Esposito D. Prescription Drug Use and Cost Among Medicaid Beneficiaries with Disabilities and Chronic Illnesses. Mathematica Policy Research. 2011. September. www.mathematica-mpr.com/publications/PDFs/health/prescriptiondrug_ib.pdf. October 18, 2013.
12 Kessler RC, Heeringa S, Lakoma MD, et al. Individual and societal effects of mental disorders on earnings in the United States: results from the National Comorbidity Survey replication. Am J Psychiatry. Jun. 2008;165(6):703-11. Epub: 2008/05/09. [pmid: 18463104].
13 Institute of Medicine. Medicare: a strategy for quality assurance. Washington, DC. National Academy Press. 1990;1.
14 Agency for Healthcare Research and Quality. Tutorials on Quality Measures. Rockville, MD. AHRQ. www.qualitymeasures.ahrq.gov/tutorial/. Feb 11, 2014.
15 Hermann R, Mattke S. Selecting indicators for the quality of mental health care at the health systems level in OECD countries. OECD Health Technical Papers. OECD Publishing. 2004;17.
16 Institute of Medicine (IOM). Improving the Quality of Health Care for Mental and Substance-Use Conditions: Quality Chasm Series. Washington DC. National Academy of Sciences. 2006.
17 Hermann RC, Mattke S, Somekh D, et al. Quality indicators for international benchmarking of mental health care. Int J Qual Health Care. Sep. Suppl 1. 2006;18:31-8. Epub: 2006/09/07. [pmid: 16954514].
18 Kilbourne AM, Keyser D, Pincus HA. Challenges and opportunities in measuring the quality of mental health care. Can J Psychiatry. Sep. 2010;55(9):549-57. Epub: 2010/09/16. [pmid: 20840802].
19 Zima BT, Murphy JM, Scholle SH, et al. National quality measures for child mental health care: background, progress, and next steps. Pediatrics. Mar. 2013;131(Suppl 1):S38-49. [pmid: 23457148].
20 National Quality Forum. National Quality Forum Home Page. Washington DC. 2014. www.qualityforum.org/Home.aspx. June 2, 2014.
21 National Committee for Quality Assurance (NCQA). HEDIS & Performance Measurement. Washington DC. NCQA. www.ncqa.org/HEDISQualityMeasurement.aspx. June 2, 2014.
22 Watkins KE, Smith B, Paddock SM, et al. Program Evaluation of VHA Mental Health Services Capstone Report The research described in this report was sponsored by the U.S. Department of Veterans Affairs and was conducted by Altarum Institute and RAND Health, a division of the RAND Corporation. Technical Report. Pittsburgh, PA. RAND Corporation. 2011. http://nowdata.cinow.info/media/uploads/2012/06/22/VHA_Mental_Health_Services_Capstone_Report.pdf. September 24, 2014.
23 Jonas DE, Mansfield AJ, Curtis P, et al. Identifying priorities for patient-centered outcomes research for serious mental illness. Psychiatr Serv. Nov. 2012;63(11):1125-30. Epub: 2012/11/03. [pmid: 23117509].
24 Agency for Healthcare Research and Quality. Varieties of Measures in NQMC. Rockville, MD. AHRQ. www.qualitymeasures.ahrq.gov/tutorial/varieties.aspx. May 15, 2014.
25 Centers for Medicare & Medicaid Services. Clinical Quality Measures (CQMs). Baltimore, MD. CMS.gov. 2014. April. 1. www.cms.gov/Regulations-and-Guidance/Legislation/EHRIncentivePrograms/2014_ClinicalQualityMeasures.html. May 15, 2014.
26 HealthIT.gov. What are clinical quality measures?. www.healthit.gov/providers-professionals/faqs/what-are-clinical-quality-measures. May 15, 2014.
27 Cooperberg MR, Birkmeyer JD, Litwin MS. Defining high quality health care. Urol Oncol. Jul-Aug. 2009;27(4):411-6. Epub: 2009/07/04. [pmid: 19573771].
28 Kelley E, Hurst J. Health care quality indicators project. Organisation for Economic Co-operation and Development OECD Health Working Papers, No. 23. Paris. 2006.
29 Perlman CM, Hirdes JP, Barbaree H, et al. Development of mental health quality indicators (MHQIs) for inpatient psychiatry based on the interRAI mental health assessment. BMC Health Serv Res. 2013;13:15. Epub: 2013/01/12. [pmid: 23305286].
30 Kilbourne AM, Fullerton C, Dausey D, et al. A framework for measuring quality and promoting accountability across silos: the case of mental disorders and co-occurring conditions. Qual Saf Health Care. Apr. 2010;19(2):113-6. Epub: 2010/02/10. [pmid: 20142404].
31 Paddison C, Elliott M, Parker R, et al. Should measures of patient experience in primary care be adjusted for case mix? Evidence from the English General Practice Patient Survey. BMJ Qual Saf. Aug. 2012;21(8):634-40. Epub: 2012/05/26. [pmid: 22626735].
32 Hargraves JL, Wilson IB, Zaslavsky A, et al. Adjusting for patient characteristics when analyzing reports from patients about hospital care. Med Care. Jun. 2001;39(6):635-41. Epub: 2001/06/19. [pmid: 11404646].
33 O'Malley AJ, Zaslavsky AM, Elliott MN, et al. Case-mix adjustment of the CAHPS Hospital Survey. Health Serv Res. Dec. 2005;40(6 Pt 2):2162-81. Epub: 2005/12/01. [pmid: 16316443].
34 Williams TL, Cerese J, Cuny J, et al. Outcomes of an initial set of standardized performance measures for inpatient mental health. Jt Comm J Qual Patient Saf. Jul. 2008;34(7):399-406. Epub: 2008/08/06. [pmid: 18677871].
35 Killaspy H, Marston L, Omar RZ, et al. Service quality and clinical outcomes: an example from mental health rehabilitation services in England. Br J Psychiatry. Jan. 2013;202(1):28-34. Epub: 2012/10/13. [pmid: 23060623].
36 Lind A. Measuring Quality for Complex Medicaid Beneficiaries in New York. New York. Medicaid Institute™ at United Hospital Fund. 2011.
37 Brown JD, Barrett A, Ireys H, et al. Evidence-Based Practices for Medicaid Beneficiaries with Schizophrenia and Bipolar Disorder. Washington, DC. U.S. Department of Health and Human Services. 2012. http://aspe.hhs.gov/daltcp/reports/2012/ebpsbd.pdf.
38 Simon S, Croghan T, Saunders RC, et al. Developing Quality Measures for Medicaid Beneficiaries with Schizophrenia: Final Report. Washington, DC. U.S. Department of Health and Human Services. 2012. http://aspe.hhs.gov/daltcp/reports/2012/schqm.shtml.
39 Charlwood P. Severe mental illness report of a working group to the Department of Health. National Centre for Health Outcomes Development (United Kingdom). London. 1999. http://hdl.handle.net/10068/547224.
40 Addington DE, McKenzie E, Wang J, et al. Development of a core set of performance measures for evaluating schizophrenia treatment services. Psychiatr Serv. Jun. 2012;63(6):584-91. Epub: 2012/04/06. [pmid: 22476226].
41 Andresen R, Caputi P, Oades L. Stages of recovery instrument: development of a measure of recovery from serious mental illness. Aust N Z J Psychiatry. Nov-Dec. 2006;40(11-12):972-80. Epub: 2006/10/24. [pmid: 17054565].
42 Kilbourne AM, Farmer Teh C, Welsh D, et al. Implementing composite quality metrics for bipolar disorder: towards a more comprehensive approach to quality measurement. Gen Hosp Psychiatry. Nov-Dec. 2010;32(6):636-43. Epub: 2010/11/30. [pmid: 21112457].
43 Owen RR, Thrush CR, Kirchner JE, et al. Performance measurement for schizophrenia: adherence to guidelines for antipsychotic dose. Int J Qual Health Care. Dec. 2000;12(6):475-82. Epub: 2001/02/24. [pmid: 11202601].
44 Duffy FF, Narrow W, West JC, et al. Quality of care measures for the treatment of bipolar disorder. Psychiatr Q. Fall. 2005;76(3):213-30. Epub: 2005/08/06. [pmid: 16080418].
45 Agency for Healthcare Research and Quality. National Quality Measures Clearinghouse. AHRQ. www.qualitymeasures.ahrq.gov/. June 2, 2014.
46 The Joint Commission. Performance Measurement. Washington DC. The Joint Commission. 2014. www.jointcommission.org/performance_measurement.aspx. June 2, 2014.
47 Adams P, Nielson H. Evidence based practice: decreasing psychiatric revisits to the emergency department. Issues Ment Health Nurs. Aug. 2012;33(8):536-43. Epub: 2012/08/02. [pmid: 22849781].
48 Owen RR, Thrush CR, Hudson TJ, et al. Using an explicit guideline-based criterion and implicit review to assess antipsychotic dosing performance for schizophrenia. Int J Qual Health Care. Jun. 2002;14(3):199-206. Epub: 2002/07/11. [pmid: 12108530].
49 Center for Quality Assessment & Improvement in Mental Health (CQAIMH). Home Page. www.cqaimh.org. February 9, 2014.
50 Druss BG, Miller CL, Pincus HA, et al. The volume-quality relationship of mental health care: does practice make perfect?. Am J Psychiatry. Dec. 2004;161(12):2282-6. Epub: 2004/12/01. [pmid: 15569901].
51 Plever S, McCarthy I, Emmerson B, et al. Clinical Practice Improvement Payments: incentives for delivery of quality care. Australas Psychiatry. Oct. 2012;20(5):407-12. Epub: 2012/09/28. [pmid: 23014128].
52 Barnes TR, Paton C, Hancock E, et al. Screening for the metabolic syndrome in community psychiatric patients prescribed antipsychotics: a quality improvement programme. Acta Psychiatr Scand. Jul. 2008;118(1):26-33. Epub: 2008/06/28. [pmid: 18582345].
53 Watkins K, Horvitz-Lennon M, Caldarone LB, et al. Developing medical record-based performance indicators to measure the quality of mental healthcare. J Healthc Qual. Jan-Feb. 2011;33(1):49-66. quiz -7.Epub: 2011/01/05. [pmid: 21199073].
54 Buchanan RW, Kreyenbuhl J, Kelly DL, et al. The 2009 schizophrenia PORT psychopharmacological treatment recommendations and summary statements. Schizophr Bull. Jan. 2010;36(1):71-93. Epub: 2009/12/04. [pmid: 19955390].
55 Brown J, Barrett A, Ireys H, et al. Evidence-Based Practices for Medicaid Beneficiaries with Schizophrenia and Bipolar Disorder. Washington, DC. Mathematica Policy Research. April. 2012. Available at aspe.hhs.gov/daltcp/reports/2012/ebpsbd.shtml.
56 Lehman AF, Steinwachs DM. Patterns of usual care for schizophrenia: initial results from the Schizophrenia Patient Outcomes Research Team (PORT) Client Survey. Schizophr Bull. 1998;24(1):11-20. discussion -32. Epub: 1998/03/21. [pmid: 9502543].
57 Valenstein M, Copeland LA, Blow FC, et al. Pharmacy data identify poorly adherent patients with schizophrenia at increased risk for admission. Med Care. Aug. 2002;40(8):630-9. Epub: 2002/08/21. [pmid: 12187177].
58 Valenstein M, Ganoczy D, McCarthy JF, et al. Antipsychotic adherence over time among patients receiving treatment for schizophrenia: a retrospective review. J Clin Psychiatry. Oct. 2006;67(10):1542-50. Epub: 2006/11/17. [pmid: 17107245].
59 Busch AB, Frank RG, Sachs G. Bipolar-I depression outpatient treatment quality and costs in usual care practice. Psychopharmacol Bull. 2008;41(2):24-39. Epub: 2008/08/01. [pmid: 18668015].
60 Druss BG, Zhao L, Cummings JR, et al. Mental comorbidity and quality of diabetes care under Medicaid: a 50-state analysis. Med Care. May. 2012;50(5):428-33. Epub: 2012/01/10. [pmid: 22228248].
61 Reilly S, Planner C, Gask L, et al. Collaborative care approaches for people with severe mental illness. Cochrane Database Syst Rev. 2013;(11).
62 Moeller KE, Rigler SK, Mayorga A, et al. Quality of monitoring for metabolic effects associated with second generation antipsychotics in patients with schizophrenia on public insurance. Schizophr Res. Mar. 2011;126(1-3):117-23. Epub: 2010/12/21. [pmid: 21168994].
63 Geraghty EM, Franks P, Kravitz RL. Primary care visit length, quality, and satisfaction for standardized patients with depression. J Gen Intern Med. Dec. 2007;22(12):1641-7. Epub: 2007/10/09. [pmid: 17922171].
64 Kaplan K, Salzer MS, Brusilovskiy E. Community participation as a predictor of recovery-oriented outcomes among emerging and mature adults with mental illnesses. Psychiatr Rehabil J. Winter. 2012;35(3):219-29. Epub: 2012/01/17. [pmid: 22246120].
65 Busch AB, Frank RG, Lehman AF. The effect of a managed behavioral health carve-out on quality of care for medicaid patients diagnosed as having schizophrenia. Arch Gen Psychiatry. May. 2004;61(5):442-8. Epub: 2004/05/05. [pmid: 15123488].
66 Powell AA, White KM, Partin MR, et al. Unintended consequences of implementing a national performance measurement system into local practice. J Gen Intern Med. Apr. 2012;27(4):405-12. [pmid: 21993998].
67 Kerr EA, Lucatorto MA, Holleman R, et al. Monitoring performance for blood pressure management among patients with diabetes mellitus: too much of a good thing?. Arch Intern Med. Jun. 25. 2012;172(12):938-45. [pmid: 22641246].
68 Seymour E. Keys to engagement Review of care for people with severe mental illness who are hard to engage with services. London. Sainsbury Centre for Mental Health. 1998. http://hdl.handle.net/10068/430835.
69 Bella M, Somers SA, Llanos K. Providing Behavioral Health Services to Medicaid Managed Care Enrollees. Options for Improving the Organization and Delivery of Services. New York. Medicaid Institute™ at United Hospital Fund. 2009.
70 Goldberg RW, Kreyenbuhl JA, Medoff DR, et al. Quality of diabetes care among adults with serious mental illness. Psychiatr Serv. Apr. 2007;58(4):536-43. Epub: 2007/04/07. [pmid: 17412857].
71 Whyte S, Penny C, Phelan M, et al. Quality of diabetes care in patients with schizophrenia and bipolar disorder: cross-sectional study. Diabet Med. Dec. 2007;24(12):1442-8. Epub: 2007/11/29. [pmid: 18042084].
72 Deuschle M, Paul F, Brosz M, et al. Assessment of cardiovascular disease risk in patients with schizophrenia spectrum disorders in German psychiatric hospitals: results of the pharmacoepidemiologic CATS study. Soc Psychiatry Psychiatr Epidemiol. 2013;48(8):1283-8. [pmid: 23515714].
73 DeLiberty RN, Newman FL, Ward EO. Risk adjustment in the Hoosier Assurance Plan: impact on providers. J Behav Health Serv Res. Aug. 2001;28(3):301-18. Epub: 2001/08/11. [pmid: 11497025].
74 Kilbourne AM, Post EP, Bauer MS, et al. Therapeutic drug and cardiovascular disease risk monitoring in patients with bipolar disorder. J Affect Disord. Sep. 2007;102(1-3):145-51. Epub: 2007/02/06. [pmid: 17276514].
75 Gierisch JM, Nieuwsma JA, Bradford DW, et al. Interventions to Improve Cardiovascular Risk Factors in People With Serious Mental Illness. AHRQ Pulication No.13-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2013. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12013022147/frame.html.
76 Barley E, Borschmann R, Walters P, et al. Interventions to encourage uptake of cancer screening for people with severe mental illness. Cochrane Database Syst Rev. 2013;(7).
77 Davidson LE. Effectiveness and cost-effectiveness of peer mentors in reducing hospital use. Yale University. Report No: 5R01MH091453-04. New Haven, CT. 2013.
78 Lucksted A. RCT to Improve Internalized Stigma and Services Engagement Among People with SMI. University of Maryland Baltimore. Report No: 5R01MH090036-03. Baltimore, MD. 2013.
79 Salyers MP. A Pilot Test of Commonground Based Shared Decision-Making. Indiana University -Purdue University at Indianapolis. Report No: 5R34MH093563-03. Indianapolis, IN. 2011.
80 Gaudiano BA. Effectiveness of Psychosocial Treatment for Inpatients with Psychosis. Butler Hospital. Report No: 1R34MH097987-01A1. Providence, RI. 2013.
81 Druss BG. Improving Primary Care of Patients With Mental Disorders. Emory University. Report No: 5R01MH070437-09. Atlanta, GA. 2013.
82 Sajatovic MX. Improving Outcomes for Individuals with Serious Mental Illness and Diabetes. Case Western Reserve University. Report No: 5R01MH085665-03. Cleveland, OH. 2013.
83 Bynum JPW. Healthcare Efficiency Among High Need, High Cost Patients. 2P01AG019783-11 Sub-Project ID: 7805. Hanover, NH. 2013.
84 Burns ME. Converting Public Health Insurance into Guideline-Concordant Mental Health Care. University of Wisconsin-Madison. Report No: 5K01MH092338-04. Madison, WI. 2013.
85 Green CA. Understanding Disparities in Preventive Services for Patients with Mental Illness. Kaiser Foundation Research Institute. Report No: 5R01MH096795-02. Oakland, CA. 2013.
86 Wilkinson EK, McColl A, Exworthy M, et al. Reactions to the use of evidence-based performance indicators in primary care: a qualitative study. Qual Health Care. Sep. 2000;9(3):166-74. [pmid: 10980077].
87 Chatterjee P, Joynt KE. Do cardiology quality measures actually improve patient outcomes?. J Am Heart Assoc. 2014;3(1):e000404. [pmid: 24510114].
88 Gillam SJ, Siriwardena AN, Steel N. Pay-for-performance in the United Kingdom: impact of the quality and outcomes framework: a systematic review. Ann Fam Med. Sep-Oct. 2012;10(5):461-8. [pmid: 22966110].
89 Lin KW. Do electronic health records improve processes and outcomes of preventive care?. Am Fam Physician. May. 15. 2012;85(10):956-7. [pmid: 22612045].