# Methods

Systematic reviews require some certainty around definitional issues and a body of studies to advance understanding of important issues. Technical Briefs, by contrast, are appropriate products for nascent fields with large uncertainties around definitional issues and limited or no evidence, precisely because they focus on uncertainties in definition, context, and outcomes. A Technical Brief does not attempt to rate the risk of bias of individual studies or grade the strength of the evidence of the literature. The purpose of a Technical Brief is to provide an overview of key issues related to the intervention such as current indications, relevant patient populations and subgroups of interest, outcomes measured, and contextual factors that may affect decisions regarding the intervention. Technical Briefs integrate targeted searches of the published literature and gray literature (i.e., non-peer-reviewed material) on the nature, context, and future research directions of quality measure (QM) use for serious mental illness (SMI) (Guiding Questions [GQs] 1, 2, and 4) with discussions with Key Informants (KIs). We also conducted a comprehensive and systematic literature review to examine whether QMs improve outcomes (GQ 3).

## Discussions With Key Informants

In consultation with our team and the Agency for Healthcare Research and Quality (AHRQ), we identified distinct perspectives that were needed to inform the development of a Technical Brief on this topic. Specifically, we sought to recruit the following as KIs: clinical providers, quality measurement implementation researchers, QM developers, QM endorsers, policymakers, patient advocates, and financing and reimbursement experts.

The KIs were particularly useful for shaping the Technical Brief because little empirical evidence exists about QMs available to assess the outcomes of serious mental illness. The KIs contributed to understanding the current state of the art of various QMs for SMI and to describe the evidence supporting their use.

The 11 KIs whom the Evidence-based Practice Center interviewed represented various fields of expertise related to outcomes of serious mental illness: clinical providers (n=2), quality measurement implementation researchers (n=4), QM developers (n=1), QM endorsers (n=2), policymakers (n=1), financing and reimbursement experts (n=2), and patient advocates (n=1). Some KIs represented multiple fields of expertise. More detail about the KI process is available in Appendix A.

## Literature Review

### Gray Literature Search

We searched the gray literature to identify information beyond the published literature on QMs in treatment of SMI. Sources for the gray literature included the following: HAPI, OpenSIGLE, ClinicalTrials.gov, Academic Search Complete, NIH RePORTER and ERIC. Appendix A provides a brief description of each of these sources. We also conducted targeted searches of Web sites of the National Guidelines Clearinghouse, the National Quality Measures Clearinghouse (NQMC), The Joint Commission, and the Center for Quality Assessment and Improvement in Mental Health(CQAIMH). See Appendix A for descriptions of these gray literature sources.

### Published Literature Search

An experienced research librarian developed our search strategy (Appendix B). We systematically searched the published literature for information for GQ 3 from inception through August 13, 2014. We searched in PubMed (MEDLINE), Excerpta Medica (EMBASE), PsycINFO, and the Cochrane Library. We reviewed the reference lists of relevant papers, and we examined any literature suggested by KIs. Our research librarian also conducted systematic searches based on references suggested by KIs. We will update the literature review by repeating our searches concurrent with the peer review process.

### Eligibility Criteria

Given the previously expressed concerns about the limited evidence base,23 we carefully considered how best to define our eligibility criteria to both reflect the current state of the art on the current and potential future use of QMs in the SMI population (GQs 1, 2, and 4) while considering the current evidence base linking QMs to improved outcomes (GQ 3).

Accordingly, we developed slightly different criteria for these two sets of questions (Table 1 describes these criteria). For GQs 1, 2, and 4, to ensure that we captured the spectrum of current thinking and evidence for the area, we broadened our definition of SMI to include those studies likely to meet our SMI definition but which did not discretely identify psychiatric diagnoses that did not meet our SMI definition. Specifically, we elected to treat studies with undefined SMI or psychiatric hospitalization as inclusions: their likely inclusion of SMI populations of interest to us allowed us to cast a wider net. However, we excluded studies that clearly did not meet our SMI population definition. If the study populations clearly included diagnoses outside of our SMI definition (e.g., posttraumatic stress disorder or dementia) or clearly excluded our populations of interests (i.e., psychotic disorders, bipolar disorders, or major depressive disorder [MDD] with psychotic symptoms), we excluded those articles. Furthermore, we applied no study design restrictions because we anticipated that relevant information might come from a variety of publications, including review articles, qualitative research, and opinion pieces. Finally, we did not require articles to report on outcomes.

Table 1 Eligibility criteria

Criterion | Inclusion | Exclusion
Population | GQs 1, 2, and 4; ■ ≥ 18 years; ■ with SMI (defined as a psychotic disorder, bipolar disorder, or MDD with psychotic features); or with serious and persistent mental illness (SPMI) but the specific psychiatric diagnose was not provided; or if SMI or SPMI is not specified but the patients had a psychiatric hospitalization. | GQs 1, 2, and 4; ■ <18 years; ■ Study defines SMI or SPMI and clearly includes diagnoses not limited to one of the three included diagnoses: psychotic disorder, bipolar disorder, or MDD with psychotic features; ■ Study specifically excludes psychotic disorders or bipolar disorders; ■ Study focuses on PTSD, dementia, or inpatients with MDD (who are in acute crisis)
| GQ 3 ≥ 18 years with SMI currently or at any time during the past year (SMI defined as [1] schizophrenia or schizoaffective disorder [or other related primary psychotic disorder]; [2] bipolar disorder; or [3] MDD with psychotic features, per DSM-IV or their ICD-9-CM equivalent [and subsequent revisions]. Requires functional impairment that substantially interferes with or limits one or more major life activities.) | GQ 3; ■ <18 years; ■ Primary diagnosis of substance abuse, dementia, personality disorder, or mental retardation without SMI
Intervention | All GQs; ■ Interventions that employ QMs or interventions that examine how documentation (e.g., electronic health records) affects the use of QMs. | All GQs; ■ Interventions that the use of QMs do not specify
Comparator | GQs 1, 2, and 4; ■ No limitations; GQ3; ■ Interventions that meet eligibility criteria (for head-to-head comparisons) and do not employ QMs | GQs 1, 2, and 4; ■ Not applicable; GQ3; ■ No comparison group
Outcomes | GQs 1, 2, and 4; ■ No limitations; GQ 3; ■ Psychiatric outcomes: Intermediate outcomes (e.g., symptom improvement, remission, adherence, tolerability); long-term outcomes (length of time in remission, decreased morbidity and mortality from psychiatric diagnosis); ■ Medical health outcomes: Intermediate; long term (e.g., decreased morbidity and mortality from medical illness); ■ Patient-centered outcomes: Intermediate; long term; ■ Clinician standard of care (e.g., use of guidelines or evidence-based care); ■ Changes in structure of health care delivery system (e.g., colocation of medical and psychiatric care); ■ Adverse effects of using QMs | GQs 1, 2, and 4; ■ Not applicable; GQ 3; ■ Outcomes not attributable to the QMs
Timeframes | GQs 1, 2, and 4; ■ No limitations; GQ 3; ■ Short term (≤ 6 months), intermediate term, and long term (≥12 months) | GQs 1, 2, and 4; ■ Not applicable; GQ3; ■ None
Setting | All GQs; ■ Inpatient or outpatient, primary care or mental health (specialty) care | All GQs; ■ None
Study design | GQs 1, 2, and 4; ■ No limitations; GQ 3; ■ Systematic reviews; ■ Randomized controlled trials; ■ Nonrandomized controlled trials; ■ Prospective and retrospective cohort; ■ Case-control studies; ■ Cross-sectional studies; ■ Pre-post studies | GQs 1, 2, and 4; ■ Not applicable; GQ 3; ■ Case reports; ■ Case series; ■ Opinions; ■ Commentaries; ■ Nonsystematic reviews; ■ Letters to the editor with no primary data
Other | ■ English language | ■ Non-English language

Abbreviations: DSM-IV=Diagnostic and Statistical Manual of Mental Disorders, 4th Edition; GQ = Guiding Question; ICD-9-CM-International Classification of Diseases, Ninth Revision, Clinical Modification; MDD = major depressive disorder; PTSD = posttraumatic stress disorder; QM = quality measure; SMI = serious mental illness; SPMI = serious and persistent mental illness.

Using these broader criteria, we reviewed all abstracts for articles with potential relevance to GQs 1, 2, and 4. We obtained the full text of any abstract addressing one or more parts of these GQs. We reviewed the full-text articles using the same broader criteria, documenting reasons for exclusion or tagging the specific GQ that the article addressed.

We developed stricter eligibility criteria for our review of evidence on the effectiveness of QMs for SMI (GQ 3). For these studies, we required that the study population be of adults with SMI (schizophrenia or schizoaffective disorder [or other related primary psychotic disorder]; bipolar disorder; or MDD with psychotic features, per DSM-IV or their ICD-9-CM equivalent). Eligible interventions were those that employ QMs or interventions that examine how documentation (e.g., electronic health records) affects the use of QMs and were either head-to-head comparisons or compared with interventions that did not employ QMs. We required studies to address one of the specified outcomes of interest (see Table 1). Study designs eligible for GQ 3 included a wide range of designs from systematic reviews to pre-post studies (see Table 1), but case reports, case series, opinions, commentaries, letters to the editor, and nonsystematic reviews were excluded.

For GQ 3, two trained members of the research team independently reviewed all abstracts for eligibility based on the pre-established inclusion/exclusion criteria. Studies marked for possible inclusion by either reviewer underwent full-text review. Any study with inadequate information in the abstract also underwent full-text review. We retrieved and reviewed the full text of all articles included during the title/abstract review phase. Two trained members of the research team independently reviewed each full-text article for inclusion or exclusion on the basis of the eligibility criteria. Disagreements about inclusion were resolved by discussion or consensus with review by the full research team as needed.

### Data Management and Abstraction

All results were tracked in the EndNote database. We recorded the reason that each excluded full-text publication did not satisfy the eligibility criteria (Appendix C). We did not abstract data into a template because we did not identify any studies that met our inclusion criteria for GQ 3. If we identify eligible studies during our update search, we will abstract data from each included study using a standardized template, capturing the following information: author, year of publication, source of study funding, study design characteristics, study population (including study inclusion and exclusion criteria), interventions employing QMs, how documentation affects use of QMs, duration of patient followup, outcomes assessed (specific measures used, as well as timing of assessment), and other pertinent information. One member of the research team will collect the data, and a second team member will review them for accuracy and completeness.

We also compiled a list of QMs that have been identified for use in SMI populations. First, we accessed the five primary QMs databases (NQMC, CQAIMH, NQF, NCQA and the Joint Commission). We abstracted the following information: quality of care concern, type of SMI, the full QM, Developer, Evidence for the Measure, and Current Use. Second, for the QMs addressed in those studies identified in our literature search, we abstracted the following information: quality of care concern, type of SMI, Developer/User of Measure for Study, Data Source, and Study Details (Appendix D).