# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officers, Carmen Kelly, Pharm.D, M.P.H., R.Ph. and Aysegul Gozu, M.D., M.P.H. We thank Doctors Kelly and Gozu and our Associate Editor, Timothy Wilt, M.D., M.P.H., for their helpful comments on a draft version of the report.

The authors deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at the RTI–UNC EPC. We express our gratitude to the following individuals for their contributions to this project: Loraine Monroe, Sharon Barrell, M.A., and Laura Small, B.A., of RTI, and Rachael Posey, M.S.L.S., of UNC.