# Findings

Because of the lack of certainty and consistency of definitions in this area, we attempted to identify the currently used definitions and concepts and to elicit input on future research and next steps in the field. Accordingly, as noted previously, for Guiding Questions (GQs) 1, 2, and 4, we looked beyond systematic and narrative reviews to qualitative research and opinion pieces. We elicited feedback from Key Informants (KIs) on what can be done and their ideas on what should be done. However, the findings from this Technical Brief should not be construed as making recommendations. It provides an early objective description of the state of science, a summary of ongoing research, information on future research needs, and suggestions of potential ways to advance the field.

Below, we focus on how the available literature addressed the GQs and integrate relevant key themes emphasized by the KIs.

## GQ 1 Description of Quality Measures

### GQ 1a Defining, Identifying, and Implementing Quality Measures

We found limited evidence on defining and implementing QMs and considerably more evidence on identifying QMs. We did not find an agreed upon list of preferred and relevant QMs for the SMI population, a finding confirmed by our KIs.

#### Defining Quality Measures

No uniformly accepted definitions of QMs in SMI exist. Rather, QMs have a variety of definitions, primarily informed by the measure's role in a particular situation.24-28 We found support for the use of Donabedian's Structure-Process-Outcome model for defining types of QMs in SMI.29,30 Expert insight suggests that an important consideration in choosing among process- and outcome-based measures is that outcome-based measures for SMI that do not adjust for case-mix may lead providers to take on easier cases or penalize practices with more vulnerable populations, just as has been found in primary31 and inpatient care.32,33 The selection of process-based measures (which we refer to here as intermediate, or proxy, outcomes), on the other hand, requires that these process measures be clearly linked to clinical and functional outcomes. In other words, the scientific basis of the measure and its clinical importance are important considerations for defining QMs.34

The focus of this Technical Brief is on the relationship between use of QMs and improved outcomes. Accordingly, we carefully considered how best to apply Donabedian's model to the use of QMs. Given that the time and effort associated with wide dissemination, uptake, and maintenance of QMs necessitates that they reflect improved outcomes, not just improved structure or process, we emphasize the role of outcomes.

#### Identifying Quality Measures

QMs are currently identified through existing assessment systems, claims data, and toolkits. For instance, in one study, the authors derived mental health quality indicators by performing retrospective analysis on datasets containing assessments from the Resident Assessment Instrument Mental Health tool.29 In another study of mental health rehabilitation services in England, researchers assessed quality of care using a Web-based toolkit, which includes seven domains of care for patients with complex mental health problems.35 In the United States, studies have used paid claims data to identify gaps in the care of SMI patients as well as to identify the extent to which patients receive evidence-based treatments.36,37 One caveat to use of claims data is that many evidence-based treatments do not have specific billing codes that distinguish them from non-empirically supported interventions

QMs may be developed using a step-by-step process that may include a subset or all of the following steps: refining and agreeing on a definition of SMI; reviewing medical records, evidence-based practices and guidelines, measures, and/or quality improvement initiatives; developing concepts and measures (clarifying the numerator and the denominator) with expert panel contributions; and obtaining input from various key stakeholders;34,38-44 and testing the measure on a dataset to determine feasibility and validity.

Although a number of QMs have been proposed for the SMI, the literature did not provide a consensus on which QMs should be used. KIs agreed that there was no such agreement on the most relevant or feasible QMs.

Sources for QMs include the following:

- AHRQ's National Quality Measure Clearinghouse (NQMC)45
- National Quality Forum (NQF), which reviews, endorses, and recommends performance measures20
- National Committee for Quality Assurance (NCQA)21
- The Joint Commission, an independent not-for-profit organization46
- Center for Quality Assessment and Improvement in Mental Health(CQAIMH) supported by AHRQ49

#### Implementing Quality Measures

Although we did not find direct evidence from literature on how QMs should be implemented, one study noted that large anticipated changes in reimbursement policies from a quantity-driven system to a quality-driven one will link payment to objective QMs.47 Rapid change in the policy and reimbursement environment fuels the urgency of implementing QMs that are not redundant, inappropriate for or burdensome for SMI.44 When organizations, such as the Centers for Medicare & Medicaid Services (CMS), mandate reporting of data for reimbursement purposes motivating providers to implement QMs becomes less of a concern. The link between implementing QMs and improving quality of care remains unclear.

### GQ 1b Important Outcomes Against Which QMs Are To Be Measured

Appendix D provides a compiled list of the QMs relevant to SMI care from both gray and published literature (empirical studies found during the GQ 3 search) sources. Potential outcomes against which QMs are to be measured are categorized as psychiatric, medical, or patient-centered. Mental health providers traditionally administer psychiatric outcome measures and assess the potential adverse events from psychiatric treatment. Medical outcomes generally assess health issues related to comorbid medical illness. Patient-centered outcomes reflect outcomes that often are of greater interest to patients and their families. These outcome categories are not completely distinct and may overlap at times but often can be seen as more likely representing a particular category. For example, level of functioning might be considered a psychiatric outcome as well as a patient outcome, but the patient or family may be more concerned with its measurement than the mental health provider.

As noted earlier, these outcomes—the ultimate goals for treatment—can be challenging to assess. Consequently, proxies for patient's health status (e.g., refills as a measure of adherence), that really evaluate processes of care or service use and are thought to be an intermediate step towards improved outcome, sometimes serve as outcomes against which QMs are evaluated. In the SMI population, more proxy (or process, or intermediate) measures are available, likely because they are more feasible and easier to collect. The likelihood of use varies somewhat by type of outcome.

For psychiatric outcomes, the literature primarily describes the use of proxies (see list below), with limited discussion of actual outcome measures. Also, the literature distinguished between psychiatric measures that measured either disease-specific (e.g., whether an antipsychotic was prescribed within the recommended dosage range for that disorder30,43,48) or more general processes of care (e.g., whether patient had outpatient mental health followup visit after hospital discharge).20,21,34,36,38,42,45,49-51 Of note, while there are a number of approved general measures for MDD symptoms,20 we did not identify any approved QMs that measure depression symptoms in patients specifically having MDD with psychotic symptoms (meeting our definition of SMI).

For medical outcomes, the literature (see bulleted list below) indicated that a number of intermediate outcomes (e.g., hemoglobin[Hg] A1c,20,21,45,49,52,53 lipid values30,37,38,45,52,53) are commonly used. Not only are these readily available intermediate proxies more easily measured than psychiatric outcomes, they are also more easily measured than many patient-centered outcomes.

Patient-centered outcomes, which by their nature tend to be more outcome- than proxy-focused, are believed to be the most important.23 These outcomes include engagement, recovery, personal empowerment, tolerance of treatments, functional measures, and quality of life measures. These measures involve both inpatient and outpatient treatment, unless they are specified otherwise (e.g., only inpatient).

Assessing these patient-centered outcomes represents a significant time and resource challenge, and may be especially difficult to improve in severe SMI groups, so using them to assess the effectiveness of QMs may be difficult and carry unintended consequences. KIs offered insight into this issue. They suggested that linking QMs to best practices or outcomes depends on context. Generally, evaluating change in outcomes is of primary importance. However, focusing on outcomes and incentivizing providers based on whether those outcomes demonstrably improve may result, for example, in penalizing providers for working with more challenging cases and holding providers accountable for downstream outcomes over which they may have little control (e.g., employment, housing). KI input suggested that in such situations, process measures such as fidelity to best practices or well-established treatment guidelines (for example, the schizophrenia guidelines)54 may be preferable.

#### Psychiatric Outcomes

##### Global Outcomes

Studies report the following global psychiatric outcomes as important to assess for patients with SMI:

- Global Outcomes
  ○ Assessment of coexisting depression or anxiety symptoms20,40,45,49
  ○ Functional assessment20,49
- Global Proxy Measures (Intermediate outcomes)
  ○ Monitoring for side effects from psychotropic medications35,40,42,49
  ○ Assessment of medication use:37,49 number of psychotropic medications prescribed (to assess risk for polypharmacy),20,34,45,46,49 adherence to medications20,21,37,38,49
  ○ Prescription of antidepressant or antianxiety medications for identified comorbid depression or anxiety,44,45,49 and assessment for trauma history42,45,46
  ○ Screening for risk of suicide20,42,45,46,49 and violence toward others45,46
  ○ Screening for co-occurring substance use20,30,34,40,42,45,49,53 and receipt of outpatient substance abuse treatment after hospital discharge30
  ○ Episodes/hours of seclusion or physical restraint while hospitalized Care after hospital discharge: continuing care plan,20,45,46 care plan provided to the next level of care clinician or entity,20,34,45,46 agreed upon comprehensive care plans between patients their family or caregivers as appropriate,34,35,45 outpatient mental health followup visits after discharge from a psychiatric hospitalization,20,21,34,36,38,42,45,49-51; rehospitalization rates,39,40,47 relapse monitoring plans,40,49 monitoring of patients lost to followup39
  ○ Referral to case management38,40,53 or Assertive Community Treatment team,37,38,49,55 as indicated

##### Specific Outcomes

For patients with schizophrenia, studies suggested the following additional outcomes:

- Specific Outcomes
  ○ Percentage of individuals with first-episode psychosis detected within 6 months of onset of psychotic symptoms.40
- Specific Proxy Measures (Intermediate outcomes)
  ○ Prescription of an antipsychotic within the recommended dosage range30,43,48 or justification for antipsychotic prescribing outside recommended practices49 (e.g., two or more antipsychotics,38,45,46,49 doses outside of recommended range,49 medication change to address severe symptoms or side effects49)
  ○ Conformance of care with evidence-based treatment recommendations56
  ○ Adherence to medications as reflected by Medication Possession Ratio57,58
  ○ Duration of untreated psychosis before treatment (which measures the appropriate initiation of antipsychotic treatment),45 creation of a relapse prevention plan,40 examination by psychologist for cognitive functioning,45 referral for cognitive behavioral therapy for psychosis45

For patients with bipolar disorder, studies suggested the following additional outcomes:

- Specific Outcomes
  ○ Monitored for change in symptom complex (assess psychotic, hallucinatory, and delusional symptoms)42,49
- Specific Proxy Measures (Intermediate outcomes)
  ○ Prescription of a mood stabilizer with monitoring of therapeutic blood levels (e.g., lithium)45
  ○ Receipt of a recommended adjunctive psychosocial intervention49
  ○ Receipt of guideline concordant medication and psychotherapy treatment59

#### Medical Outcomes

Measures related to cardiovascular disease, metabolic syndrome, general medical screening/preventive care, and smoking status are critically important to measure in an SMI population because these diseases affect the SMI population at a greater rate than the general population.8 These outcomes are not disease specific, so they are listed in the “Global” category.

##### Global Outcomes

Studies report the following as important global medical outcomes to consider for patients with SMI:

- Global Outcomes
  ○ For those with diabetes,60 HgA1c and low-density lipoprotein-cholesterol (LDL-C)60
  ○ Monitoring of cardiovascular disease (CVD) with LDL-C20,45
  ○ Serum creatinine and thyroid stimulating hormone (TSH)30,45 for patients treated with lithium
- Global Proxy Measures (Intermediate outcomes)
  ○ For those with diabetes, annual foot and eye exams,30,61
  ○ Screening for hyperglycemia (blood glucose)30,37,38,45,52,62 or diabetes (HgA1c)20,21,45,49,52,53
  ○ Screening for cardiovascular disease risk (total cholesterol, high-density lipoprotein [HDL])30,37,38,45,52,53,62
  ○ Receiving a general medical exam (referred to general medical care30,35,37-40,53 coordination with general medical care providers)
  ○ Blood pressure measurement38,42,45,49,52
  ○ Screening for weight gain:38,42,45,53 body mass index (BMI),45,49,52,53 abdominal waistline measure52,63
  ○ Cancer screening37,45
  ○ Smoking status30,35,38
  ○ Receipt of general health care advice (exercise, diet, sexual health, etc.)35

#### Patient-Centered Outcomes

##### Global Outcomes

From the literature, we identified the following important global outcomes to consider for patients with SMI:

- Patient involvement in their inpatient treatment (e.g., patient identification of their problems, goals, and agreement with treatment plan, among others)34
- Receipt of psychoeducation about their illness40,45,49
- Self-management of community functioning (recovery)41
- Community inclusion (recovery)64
- Receipt of assistance for finding employment37,38,49

##### Specific Outcomes

For patients with schizophrenia, several additional patient-centered outcomes must be considered:

- Family involvement in care plans,34,35,45,49 psychotherapy,37,38,65 and psychoeducation35,40
- Receipt of psychotherapy37,65
- Amount of patient autonomy35
- Quality of life assessment39,40
- Independent Living Skills assessment53
- Housing status39

For patients with bipolar disorder, the literature described the following additional patient-centered outcomes:

- Patient report of side effects of medications42
- Reasons for patient voluntary discontinuance of medications42

Most measures of level of functioning, treatment tolerability, and quality of life are primarily considered patient centered, but can also be considered psychiatric. Of note, many KIs suggested that patient-centered outcomes are likely the most relevant and important outcomes to measure for the SMI population.

#### Should QMs Be More Strongly Linked With Fidelity to Best Practices or With Outcomes?

We did not identify any published studies that directly answered this question. However, KIs helped frame this issue. They suggested that linking QMs to best practices or outcomes depends on context. In general, measuring change in outcomes is of primary importance. However, focusing on outcomes and overly incentivizing providers may result in unintended consequences such as penalizing providers for working with more challenging cases and making it harder for those with more serious illness to obtain the care they need. KI input suggested that in such cases, process measures may be preferred where fidelity to best practices or treatment guidelines is well established (for example, the schizophrenia treatment guidelines).54

### GQ 1c Different Types of QMs Currently Used To Assess Quality of Care and Outcomes in Patients With SMI

Both the literature and the KIs identified QMs currently used, consisting mainly of process-oriented measures addressing psychiatric, medical, and patient-centered outcomes. A review of the primary QM databases (NQMC,45 Center for Quality Assessment and Improvement in Mental Health,49 NQF,20 the NCQA Health Care Effectiveness Data and Information Set [HEDIS] and Performance Measurement,21 and the Joint Commission National Quality Core Measures46) for measures currently used for SMI reveals that many of the important psychiatric and medical outcomes identified by KIs as important to measure (listed above in GQ 1b) are available. We found 16 measures that were endorsed by NQF. Among these 16 measures, 6 are core measures used by the Joint Commission as Hospital-based Inpatient Psychiatric Services measures, and 4 HEDIS measures used by CMS. Appendix D provides a compiled list of the QMs relevant to SMI care from both gray and published literature sources.

#### Potential Advantages of Currently Used QMs in Assessing Quality of Care and Outcomes in Patients With SMI

The literature detailed many potential advantages of QMs in assessing the quality of care and outcomes in patients with SMI. QMs may lead to improved patient autonomy and experience of care and are tied to better clinical outcomes.35 Composite QMs are useful to identify the point in the treatment process at which it is best to intervene.42

#### Potential Disadvantages of Currently Used QMs in Assessing Quality of Care and Outcomes in Patients With SMI

In general, the literature said little about potential disadvantages. One important potential disadvantage of QMs noted by the literature is that some QMs may not be flexible enough to address multiple goals such as adherence to guidelines and the influence of patient preferences (e.g., a patient's refusing a medication change). Therefore, a QM may indicate that a provider is not providing quality of care by one standard (e.g., consistency with evidence-based guidelines), while at the same time indicating the provision of quality care by a different standard (e.g., shared decisionmaking). Thus, the QM may place providers in the position of choosing between adhering to the guideline or adapting to the needs of their patients or circumstances.44 Also, QM data collection can also place an increased burden on health plans and pose challenges in the implementation of performance measures.44 Finally, as mentioned earlier in the GQ 1a section, KIs noted a potential disadvantage in that incentivizing providers to focus on outcomes might result in unintended consequences, such as penalizing providers for working with more challenging cases and making it harder for those with more serious illness to obtain the care they need. We did not find any literature directly addressing this concern for the seriously mentally ill. There was, however, literature that identified potential disadvantages in non-SMI populations, such as intended consequences including inappropriate clinical care, distracting providers from patient concerns, and negative effects on patient education and autonomy.66,67

### GQ 1d Factors Affecting the Implementation of Currently Used QMs

#### Barriers to the Use of QMs

The literature identified time as a main barrier to the use of QMs. As multiple QMs are accepted and incorporated into practice, the burden on existing systems will increase, as will the burden on providers. Two studies also described the time limitation as a financial and staffing barrier to implementation of measures,44,68 including lack of training.

The privacy and confidentiality of mental health information, can conflict with the data-sharing process of monitoring QMs. Accordingly, many of the existing QMs are unlikely to be quickly taken up by mental health, posing an additional significant barrier.44 The literature further detailed the challenge in refining QMs for comorbid conditions in SMI.30 Additionally, the literature identified variations in organizational and financing structures across systems of care and the lack of clear accountability for which providers need to respond to QM results as important barriers to the implementation of QMs in patients with SMI.30,44,69

The literature also provided additional potential barriers of QM use in the SMI population, including (1) the redundancy of performance measurement efforts across several arenas,44,53 (2) having questionable validity because of the unintended consequences of poor implementation (as noted above),44 and (3) the limitations in using different types of data to characterize quality. Although commonly used, administrative data can be limiting owing to the challenges of translating this form of data into clinically meaningful actions 44 Further, medical data indicators can be difficult to collect and expensive.53

Of note, despite KI concerns about how an emphasis on improved outcomes might lead providers to avoid the sickest SMI patients, the literature did not assess whether case-mix severity is a barrier to care for those with the most severe forms of SMI.

#### Facilitators to the Use of QMs

The literature found that being an evidence- and/or guideline-based QM that could be applied flexibly across SMI conditions facilitated uptake.48,65 For example, hospitalization is an effective evidence-based proxy outcome for SMI research.40,70 Further, being able to effectively integrate clinical process measures with outcome measures is another facilitator to QM use.34 In other words, the more feasible QMs are to implement, the more likely that they would be used.

The literature highlighted three main areas for facilitating QM use: (1) service improvements with financial incentives, (2) communication enhancement, and (3) patient centeredness. The use of QMs and service improvement are tied to financial incentives.51,71 Linking the level of consumer need to the level of reimbursement and implementing a documentation system are both facilitators for the use of financial incentives to improve the quality of care.30,69,72,73 An improved communication-based process plan should span the continuum of care providers. One study found that improved communication across the continuum of providers is a facilitator for QM use and can reduce ER visits. As a result, the pace of activity in ERs is slower, and the quality of care delivered is better.47 Establishing a framework to improve communication among care providers in how to best delineate their roles and the degrees of accountability in the process of SMI patient care is critical in the success of QM use for SMI.30 Finally, the literature showed that patient-centeredness in QM development and implementation could be captured in patient outcome data and consumer-based definition or oriented models, which would facilitate the use of the QMs.41,42,48

### GQ 1e Usefulness of Currently Available QMs

Although the literature did not directly address how useful various stakeholders found currently available QMs, the evidence base identified the alignment of financial incentives with use of QMs and the development of an evidence base as important parts of increasing the use of QMs. An important caveat is the understanding that evidence-based guidelines or best practices do not generally incorporate patient-centered outcomes, such as personalized needs, patient engagement, or recovery. Hence, QMs aimed at making management more guideline concordant will likely not affect these important outcomes. Of note, one study suggested integrating patient-centered measures with those measures that are based on adherence to guideline-recommended care to be more in line with the shared decisionmaking that takes place between the mental health provider and the SMI patient about clinical care.42

#### Are QMs Currently Being Used for Patient Care and Clinical Decisionmaking?

We found no studies commenting on how QMs are being used currently for SMI patients' care, nor how frequently they are being used, although KIs reported that the Veterans Affairs system routinely uses QMs in clinical decisionmaking for mental health conditions.

##### Appropriateness of QMs Use

We did not identify any studies that commented on the appropriateness of QM use in SMI.

### GQ 1f How Should QMs Be Used To Measure Outcomes Over Short-Term, Intermediate, and Long-Term Periods?

Investigators have noted the inappropriateness of using only short-term performance measures to demonstrate the quality of contracted services in the UK National Health System for a severely mentally ill population, because this group is made up of long-term users of care,68 but we did not find studies offering specific direction on how QMs should be used to measure outcomes over varied time periods.

## GQ 2 Context in Which QMs for SMI Are Used

We found no articles in the literature that predict the selection of QMs based on organizational components or characteristics of a hospital or other mental health care delivery (2a), clinical characteristics of SMI diagnosis (2b), clinician characteristics (2c), or nonclinical patient characteristics (2d). We identified several articles that mentioned resources needed to implement QMs (2e).

### GQ 2e Resources Needed To Implement Quality Measures

We found consistent support in the literature29,35,44 and KI responses that infrastructure—personnel, electronic health records, and training—was necessary to implement QMs across a larger system and would then allow for monitoring of QMs across providers.

Studies identified in the literature raised concerns about the potential for significant financial and staffing burdens on health plans as a result of performance measurement efforts.29,44 One study provided an example of resources needed to develop a Web-based tool for providers to use to collect the data needed for QMs.35 With the development of new data collection systems comes the need for training of staff to use the electronic systems. Data must be entered correctly to be a reliable source for quality improvement. Resources are needed to train the staff inputting the data, those conducting the assessments and those generating the reports.35 Even when infrastructure is already in place, QM implementation may require extensive training and ongoing technical support.29

## GQ 3 Current Evidence About the Effectiveness of QMs for SMI

We searched systematically for evidence linking the use of QMs with improvement in SMI outcomes. We identified 566 citations from database searches, gray literature searches, KI recommendations, and reviews of reference lists (Figure 1). Based on the inclusion criteria described above in Methods, we did not identify any studies that met the inclusion criteria for the effectiveness of QMs for SMI. Although some studies described the need for QMs, none actually addressed implementing a QM and evaluating any subsequent change in outcomes. In the end, the possible studies for inclusion did not address how a QM leads to better quality of care for those with SMI. Although we found studies that map to issues brought up by the KIs, they were more descriptive of the lack of proper care (e.g., SMI patients on antipsychotics not being screened for diabetes,72,74 dyslipidemia,72,74 or hypertension72). Our review of NIH Reporter and Clinicaltrials.gov did not indicate any ongoing studies that are addressing the link between QMs and improved outcomes in SMI.

Figure 1 Preferred reporting items for systematic reviews and meta-analysis (PRISMA) tree

A search of four published literature databases (PubMed, Cochrane, EMBASE and PsychINFO), gray literature databases, and hand searches yielded a total of 566 citations once duplicates were removed. The 566 citations were screened for title/abstract review. Of those, 499 were excluded as not relevant for Guiding Question 3 (GQ3) and 67 citations remained for full text review. Of the 67 citations we reviewed at the full text stage, we excluded all 67 based on the exclusion categories (ineligible language, ineligible publication type, study design or not original research, ineligible population, ineligible or no intervention, ineligible or no comparison, and ineligible outcome). We did not identify any studies that met the inclusion criteria; as a result, zero total studies were abstracted.

## GQ 4 Current Key Issues in Future Uptake, Use, Evidence Gaps, and Research Priorities for Quality Measures

Our review of the literature did not identify any articles addressing trends in uptake of QMs for SMI or expected short-term or long-term developments in this field. The literature and the KIs were generally in agreement on the gaps in the evidence base for the use of QMs in SMI. Although the literature did not address the issue, the KI interview responses showed mixed opinions on whether QMs can alter decisionmaking; many of the KIs saw potential, but others questioned whether such a link was possible given the potential for unreliability in SMI diagnoses (which QMs cannot change). A key issue is that the evidence base linking use of QMs to improved outcomes is severely limited. High-quality prospective studies are lacking, and the outcomes of most interest to many stakeholders—patient-centered outcomes such as recovery and engagement—can be challenging to measure. Although we identified articles in the literature that addressed research needs in discussions about research gaps, we did not find any articles describing how best to prioritize key areas for future research.

### GQ 4a Trends in the Uptake of QMs for SMI

KI interviews identified three key trends in the uptake of QMs: (1) use of technology in a routine manner in SMI, (2) focus on patient-centered and recovery-based outcomes, and (3) movement toward integrating physical and mental health care.

Technology-related trends include using technological platforms to capture and record relevant outcome data, and aggregate information at individual, group, or population level; enabling health care providers to use electronic health records on a routine basis; and allowing patients to provide data electronically on changes in outcomes. The patient-centered trends noted by more than half of the KIs included efforts made by measure developers to ensure that patients were included in the development and refinement of QMs. Regarding trends related to integrating mental and physical health care, a couple of KIs specifically mentioned evaluating cardio-metabolic outcomes for SMI patients for a better assessment of the physical status of SMI patients. Additionally, they described QMs as enabling better coordination of primary care and behavioral health. This would include standardization of measures across settings (e.g., ensuring that behavioral health-oriented measures do not focus on specialty providers or settings but are also applicable in other settings like primary care and nursing homes).

Other trends suggested by the KIs included the following:

- increased number of initiatives that focus on linking payment to value instead of volume (e.g., pay for performance initiatives that reward good performance on QMs and penalize poor performance);
- increased use of QMs as more providers are required to use them for various system- or payment-based purposes (e.g., because of meaningful use);
- improvement of QM fidelity and concordance of QMs with guidelines;
- increased use of measures in health plans that service Medicare and dually eligible (Medicare/Medicaid) individuals with SMI. Medicaid paid claims data are typically available to State agencies and are therefore available for States to implement QMs (e.g., pharmacy-based QMs).

### GQ 4b Gaps in the Evidence Base for Best Practices or Interventions for Quality Measures for SMI

Articles identified in the literature and KI interviews reported several evidence gaps for SMI QMs.

Several KIs emphasized that the quality measurement field has a limited evidence base to date for many QMs, which could undermine the likelihood of their use. Specific areas KIs mentioned for which there was no evidence tying QMs to improved outcomes involved the following QMs (all of which measured proxy outcomes): posthospitalization followup, measures that assess transitions of care for the SMI population, and receipt of a discharge plan.

This lack of evidence tying the use of QMs to improved outcomes echoed in a number of other related research gaps. KIs suggested that more research is needed to tie proxy measures with clinical and social outcomes. Specifically, gaps exist in the measurement of outcomes in a clinically user-friendly fashion for some of the psychosocial outcomes (e.g., independent living and social relationships).

Another theme focuses on the unclear quality of data used to develop or test QMs. Research has noted that it is difficult to isolate the effects of a particular QM from other influences such as ongoing quality improvement initiatives.51 Other data quality issues focus on the quality or validity of the dataset itself. The literature has described problems with the data sources (health plan administrative data and Medicare and Medicaid claims data) frequently used to test and assess conformance with quality indicators: they often contain data of questionable validity because of coding errors and biases in documentation.44 Others raise similar concerns about relying solely on administrative data to make broad inferences about quality.53

Another gap arises from the study designs used in the current evidence base for QMs.44 The evidence base for QMs often comes from randomized controlled trials (RCTs) testing the efficacy of interventions. However, the eligibility criteria for RCTs can be extremely stringent, yielding results of limited generalizability to typical patients. Longitudinal observational research is needed to evaluate the effectiveness of recommended care in real-world settings. Such studies would also allow researchers to examine clinical rationales for deviations from recommended care.44

More direct objections come from critics who claim that quality indicators are weak measures of health care quality because they do not address patient satisfaction.71 Several KIs observed the general absence of well-validated, easy-to-use patient-centered QMs, including patient engagement.

Some researchers have pointed out that many indicators have strong face validity but will never garner the evidence base linking them to improved outcomes, particularly indicators related to patient centeredness and recovery. To address this problem, future research should consider new ways of assessing whether QMs can successfully predict improved outcomes involving patient satisfaction and emotional well-being.53 Future research should also assess translational validity (i.e., “the certainty that the operationalization accurately reflects the process of care it is trying to capture”) and explore ways to reduce gaps between actual practice and its documentation in the medical record.53

One knowledge gap emphasized by a few KIs and echoed in the literature focused on the lack of evidence or knowledge for the efficacy of interventions to address known coexisting medical health problems in the SMI population. For example, a recent systematic review evaluated interventions to improve cardiovascular disease (CVD) risk in adults with SMI.75 Despite adults with SMI having higher rates of CVD risk factors and higher CVD mortality rates, this review found that very few studies have evaluated the effectiveness of interventions to improve CVD risk factors in the SMI population. Another recent systematic review investigated the effectiveness of interventions targeting SMI patients and focused on increasing the uptake in appropriate cancer screening tests.76 The authors found no trials meeting their inclusion criteria and concluded that large, quality RCTs “are needed urgently to help address the disparity between people with SMI and others in cancer screening uptake.”76 However, even if a QM were to identify a cardiovascular health problem, the available evidence base does not indicate what the most effective intervention is. A related area with no evidence was the lack of QM measures related to preventive care.

Researchers have proposed a framework for developing future QMs specifically for those with serious mental health disorders and co-occurring conditions (e.g., CVD) that is based on definitions of accountability,30 (i.e., who is responsible for ensuring that QMs have an impact on improving care for those with comorbid medical problems). The framework is intended to inform an agenda for future research in areas such as QM refinement for co-occurring conditions, validation of measures for integrated services, and defining accountability.

Finally, some KIs noted that research assessing the evidence base for QMs often has a low likelihood of being funded; therefore, the absence of a solid evidence base should not preclude use of QMs that have strong face validity.

### GQ 4c Prioritization of the Key Areas for Future Research

KIs identified various areas for future research, specifically developing and testing evidence-based QMs on care coordination, care planning, drug treatment, patient engagement, functioning (e.g., employment), and recovery. Several KIs also suggested specific focus areas for future research such as outcomes of drug treatment and psychotherapy quality management.

KIs also highlighted the need for future research focusing on how QMs can improve provider performance and patient decisionmaking through emerging technologies. Many KIs noted several systems-level focused areas for future research, such as (1) assessing the impact of QMs on the process of care and whether the benefits outweigh the costs (including opportunity costs), (2) combining QMs with payment mechanisms for mental health care (i.e., understanding how QMs tie into greater cost efficiency), and (3) determining the optimal ways to use data captured in electronic medical records to gauge the quality of a system.

### GQs 4d and e Expected Developments in the Field

We were not able to identify any ongoing studies assessing the link between QMs and outcomes in the SMI population. However, a number of ongoing studies of quality improvement aim to improve care and reduce excess mortality for adults with SMI that potentially could shed light on this link. Researchers are evaluating the efficacy of innovative strategies for care. Current studies assess the effectiveness of the following care strategies and interventions within SMI populations: peer support services,77 multisession psycho-education classes to reduce internalized stigma,78 shared decisionmaking medical management programs,79 Acceptance and Commitment Therapy for inpatients with psychotic disorders,80 and integrated community care models.81 An ongoing randomized controlled trial is also evaluating the effectiveness of care models and self-management strategies for individuals with SMI and co-occurring diabetes.82 Studies are additionally underway to examine the impact of health care system reform and policies on the quality, cost, and accessibility of care for adults with SMI. These include studies on the effects of system-level changes on the care for high-need, high-cost nursing home patients and Medicare and Medicaid recipients,83 simplified Medicaid enrollment and renewal requirements' effect on insurance coverage of SMI patients,84 the impact of eliminating annual visit limits for psychotherapy and medical care on service use and cost for publicly insured adults with SMI,84 whether changes in Medicaid psychiatrist fees are associated with psychiatrist participation in Medicaid and beneficiary access and use,84 and an examination of organizational- and regulatory-level factors contributing to the disparities in preventive care service use for SMI patients.85 Results of these studies may inform the development of QMs and future policy and programmatic decisions in the care of individuals with SMI.