# Background

## Prevalence, Morbidity, and Impact of Serious Mental Illness

Provisions of the Affordable Care Act (2010) require the use of validated quality measures (QMs) to evaluate the quality of health care programs, services, and outcomes.1 The impetus for program evaluation stems from a desire to determine which programs are most effective for improving patient health. The need for efficient use of limited resources is crucial in serious mental illness (SMI), where adequate treatment requires long-term followup and places a heavy demand on often-strained health care resources. Encompassing a variety of definitions,2 at its core SMI refers to a diagnosis of psychotic disorders, bipolar disorder, and major depressive disorder with psychotic features.

SMI is an important topic for several reasons. First, the prevalence and morbidity of SMI are striking. It is typically a long-term illness involving substantial functional impairment over multiple symptom domains. These impairments can lead to an inability to work, poor social relations, substance abuse, dangerous and reckless behaviors, repeated psychiatric hospitalizations, poor self-care, incarceration, and homelessness. Rates of SMI for U.S. adults range from 4 percent to 6 percent, affecting more than 11 million adults.3,4

Second, SMI and its comorbidities are frequently untreated or undertreated. Among adults with an SMI in 2008, less than 60 percent used any mental health services in the past year, and only 40 percent used any outpatient services.5 Furthermore, even in those receiving treatment, the quality of care received for both psychiatric6 and general medical conditions7 is frequently inadequate, which may be related to poor outcomes. Indeed, SMI patients die 10 to 25 years earlier than patients without these illnesses, primarily from cardiovascular disorders.8,9

Finally, the costs of SMI to patients, families, and society at large are substantial. Many SMI patients require inpatient hospitalization at multiple times in their lives, and emergency department visits are not uncommon.10 The cost of antipsychotic medications has typically been the single largest cost to most State pharmacy budgets.11 The cost in terms of lost productivity is an estimated $193 billion per year in lost earnings.12

## The Use of Quality Measures in Serious Mental Illness

One potential means of improving the delivery of quality care to SMI populations is using QMs as the agent of change. Quality of care is understood as “the degree to which health care services for individuals and populations increase the likelihood of desired health outcomes and are consistent with current professional knowledge.”13 Accordingly, QMs can be defined as measures that allow the user to quantify the quality of a particular aspect of care by comparing it with an evidence-based criterion that specifies what constitutes better quality.14 QMs are used for three general and often overlapping purposes: quality improvement, accountability, and research.14 This brief focuses on the first purpose.

For patients with SMI, the use of QMs can serve different quality improvement purposes. Some QMs measure the quality of care for SMI: these measures may address global issues that span multiple psychiatric diseases (e.g., coexisting depressive symptoms) or more disease-specific ones (e.g., auditory hallucinations). Other QMs may treat the SMI population as a high-risk population for medical problems and thus require anchoring in values for general medical populations: the measures allow the user to assess whether care in a high-risk population is adequate relative to a comparable population without SMI.

To determine whether QMs are effective, they need to be evaluated against meaningful and measurable outcomes. For SMI, these outcomes include standard psychiatric outcomes, such as disease severity, response to treatment, and development of suicidal ideas or behaviors; medical outcomes, such as the development of cardiovascular complications; and patient-centered outcomes, such as employment, psychosocial functioning, and patient autonomy (i.e., outcomes especially meaningful to patients). These categories are not rigidly exclusive. Some may consider patient-centered outcomes as psychiatric outcomes, the goal of treatment not being merely symptom reduction but, more important, return to premorbid function and community engagement. Indeed, by their nature outcomes tend to be more patient centered. The most meaningful outcomes are those that clearly demonstrate improvement in health (e.g., resolution of psychotic symptoms, successful management of diabetes, maintenance of employment), but these can vary considerably by patient (e.g., some may value employment, others may not) and be challenging to measure. As a result, proxies for patient's health status, which really measure processes of care or service use, are sometimes considered outcomes.

By using QMs to monitor the degree and quality of care being delivered to the SMI population, policymakers, clinical providers, payers, and patient advocates hope to improve health care delivery by providing feedback on areas where quality care is not being delivered. For example, SMI patients may not receive guideline-concordant screening for medical illness, monitoring for antipsychotic side effects, or assessment of functional status/improvement; by identifying whether and where these care steps are missing, QMs can help health care providers identify where access needs to be increased and/or quality of care needs to be improved.

By improving access to and delivery of quality care, the use of QMs is one potential means of improving outcomes in SMI populations. Several international and national organizations have developed QMs and guidelines that may be suitable for SMI. In 2004, an international expert group developed consensus-based measures for the Organisation for Economic Co-operation and Development countries that address aspects of care for SMI.15 In 2006, the Institute of Medicine described an approach for developing, testing, and validating QMs for mental health,16 and two key organizations, the National Committee for Quality Assurance (NCQA) and the National Quality Forum (NQF), are involved in developing and endorsing QMs based on the Institute of Medicine recommendations. As QMs have been developed, groups have used RAND Delphi methods to try to strike the important balance between validity and feasibility.17-19

In keeping with this approach, NCQA develops measures or identifies any existing measure that appears appropriate for use as a QM. This determination confirms that the QM measures what it purports to measure, but an evidence base tying the presence of this QM to improved outcomes is not required. These are subsequently forwarded to the NQF for rigorous review. Measures that meet NQF review criteria (which include validity and feasibility) are then endorsed. Many measures are not endorsed because they lack sufficient evidence to support them. NQF has endorsed 16 measures that are applicable to SMI20; 6 are used by the Joint Commission as hospital-based inpatient psychiatric services measures21 and 4 are Healthcare Effectiveness Data and Information Set measures21 established by the Centers for Medicare & Medicaid Services for mental health care provided to Medicaid patients.

In addition, the Agency for Healthcare Quality and Research sponsors the National Quality Measure Clearinghouse (NQMC), a publicly available database and Web site for evidence-based health care QMs. Each measure that meets the rigorous NQMC criteria for inclusion has a structured, standardized summary detailing the evidence supporting the measure and other background details, although this determination does not require direct evidence that the QM leads to improved outcome. The NQMC also incorporates the U.S. Department of Health and Human Services' Measure Inventory, a repository of measures used by their agencies for quality measurement, improvement, and reporting.

However, multiple potential constraints on the utility and adoption of QMs hinder their use as agents of change in the SMI population. A key consideration is the selection of a preferred outcome against which to assess the effectiveness of a QM. Although preferred outcomes may be longer-term and patient-centered, such outcomes can be challenging to measure routinely; therefore, many outcomes that are used are intermediate or proxy measures. Their use creates the possibility that improving the intermediate measure may not in fact improve patient outcomes. Indeed, there are a variety of opinions on which outcomes QMs should be assessed against, and whether these outcomes should be outcome measures or proxies for outcomes. Further, among SMI experts, the level of agreement about how to define a QM22 is low. Specifically, a spectrum of views exists about which QMs should be applied; how to select the appropriate QM; how QMs should be developed, endorsed, and implemented; and how their use affects patient-relevant outcomes. The feasibility of QM implementation is unclear, given that the increased time and resource demand on heavily burdened providers may limit uptake. Not surprisingly, although a variety of such measures for SMI have been proposed, no single measure or metric is used consistently across all treatment sites (e.g., inpatient versus outpatient settings, community mental health versus private settings) or all forms of SMI.

Hence, key areas of uncertainty remain. Knowledge gaps for SMI include generating an agreed-upon list of relevant QMs; identifying the most meaningful outcomes by which to measure the success of QMs; identifying barriers to and facilitators of their implementation; and assessing robustly whether use of such measures improves medical, psychiatric, and patient-centered outcomes. The goal of this Technical Brief is to identify how QMs are currently used in the SMI population and to describe the evidence supporting their use. To reflect the variety of QM definitions and to help identify key potential future research needs in the field, we queried the Key Informants (KIs) on their understanding of how QMs should be measured and used. Our brief will examine (1) the measures, (2) their context, (3) ongoing research, and (4) future research directions and other issues.

## Guiding Questions (GQs)

1. Describe Quality Measures (QMs)
  a. How should QMs be defined, identified, and implemented?
  b. Regarding outcomes against which QMs should be evaluated
    – What are the important psychiatric, medical, and patient-centered outcomes?
    – Should QMs be more strongly linked with fidelity to best practices or with outcomes?
  c. What are the different types of QMs currently used to assess quality of care and outcomes in patients with SMI?
  d. What factors affect the implementation of currently used QMs?
    – What are the potential advantages of each of these QMs in patients with SMI?
    – What are the potential disadvantages of each of these QMs in patients with SMI?
    – What are the barriers to their use?
    – What are the facilitators of the use of QMs?
  e. How useful are the currently available QMs?
    – Are QMs currently being used for patient care and clinical decisionmaking?
    – Are the correct QMs being used?
    – What are the necessary steps to improve the use and usefulness of QMs?
  f. How should QMs be used to measure outcomes over short-term, intermediate, and long-term periods?
2. Describe the Context in Which QMs for SMI Are Used
  a. What organizational components or characteristics of a hospital or other mental health care delivery facility affect selection of QMs?
  b. What clinical characteristics of the SMI diagnosis (e.g., schizophrenia vs. bipolar disorder) affect selection of QMs?
  c. What clinician characteristics (e.g., training, specialty, setting) affect selection of QMs?
  d. What nonclinical patient characteristics (e.g., sociodemographic characteristics, insurance status, urban/rural setting) affect selection of QMs?
  e. What resources (e.g., organizational structure, staffing, appointment availability) are needed to implement QMs?
3. Describe the Current Evidence on Whether the Use of QMs for SMI Affect Outcomes
4. Current Key Issues in Future Uptake, Use, Evidence Gaps, and Research Priorities for QMs
  a. What are the trends in uptake of QMs for SMI?
  b. What gaps exist in the evidence base for best practices or interventions for QMs for SMI?
  c. How should one prioritize the key areas for future research?
  d. What are the expected short-term developments in this field that may address these uncertainties or influence diffusion of QMs?
  e. What are potential long-term (10-year) developments in this field?