# Quality Measures for SMI

Table D-1 Identified quality measures for psychiatric care in key quality measure databases: Antipsychotic prescribed

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Prescribed an antipsychotic | Schizophrenia | Proportion of patients who have a prescription for antipsychotic medication | The Danish National Schizophrenia Registry | A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research
Prescribed an antipsychotic | Schizophrenia | Antipsychotic prescribed | CQAIMH, Developer: American Psychiatric Association | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Prescribed an antipsychotic | Schizophrenia | Antipsychotic prescribed | CQAIMH, Developer: National Association of State Mental Health Program Directors | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Prescribed an antipsychotic | Schizophrenia | Discharged from a schizophrenia hospitalization with an antipsychotic prescription | CQAIMH | AHRQ Level A: Good research–based evidence | NR
Prescribed an atypical antipsychotic | Schizophrenia | Receiving an atypical antipsychotics (clozapine, olanzapine, risperidone, quetiapine, ziprasidone) during a specified period | CQAIMH Developer: National Association of State Mental Health Program Directors | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Prescribed a depot antipsychotic | Schizophrenia | Patients receiving a depot antipsychotic who had reported noncompliance with their antipsychotic medication regimen | CQAIMH Developer: Lehman et al, 1998 | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Prescribed an antipsychotic at the right dose at Discharge | Schizophrenia | Discharged from a schizophrenia hospitalization with an antipsychotic prescription at a dosage in the range of 300 to 600 chlorpromazine equivalents per day | CQAIMH Developer: Lehman et al., 1998 | AHRQ Level A: Good research–based evidence | NR
Prescribed continuation antipsychotic | Schizophrenia | Discharged from a hospitalization and continued to receive an antipsychotic medication for the 12-month period following discharge | CQAIMH Developer: Lehman et al., 1998 | AHRQ Level A: Good research–based evidence | NR
Prescribed an antipsychotic at the right dose | Schizophrenia | Discharged from a schizophrenia hospitalization using an antipsychotic prescription at a dosage less than 150 chlorpromazine equivalents for greater than 4 weeks | CQAIMH Developer: Popkin et al., 1998 | AHRQ Level A: Good research–based evidence | NR
Documented rationale for outlier dosages of antipsychotic | Schizophrenia | All individuals 18 and older with a diagnosis of schizophrenia who are receiving antipsychotic medication at a dosage that is outside the recommended range (300 and 1,000 CPZ equivalents) at a specified point in time and whose medical record of the preceding 6 months provides documentation for the dosage used | CQAIMH | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
2 or more antipsychotics prescribed | Hospital- based inpatient psychiatric services (all ages, but can separate out adults) | Percentage of hospital-based inpatient psychiatric services: the percentage of patients discharged from a hospital-based inpatient psychiatric setting on two or more antipsychotic medications CMS: Patients discharged on multiple antipsychotic medications | Joint Commission (Core Measure) CQAIMH NQF ENDORSED (0552) NQMC: 007526 HBIPS-4 HHS:004856 | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Accreditation Collaborative inter- organizational quality improvement Internal quality improvement Public reporting
Justification provided for prescribing 2 or more antipsychotics | Hospital-based inpatient psychiatric services (all age groups but can separate out adults) | Percentage discharged from a hospital-based inpatient psychiatric setting on two or more antipsychotic medications with appropriate justification CMS: Patients discharged on multiple antipsychotic medications with appropriate justification | Joint Commission (Core Measure) CQAIMH NQMC: 07527 HBIPS-5 HHS:004855 | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Accreditation Care Coordination Collaborative inter- organizational quality improvement Public reporting

Table D-2 Quality measures used in studies for assessing psychiatric care: Antipsychotic prescribed or used

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Data Source | Study Details
Prescribed antipsychotic | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Number (%) of patients receiving typical and atypical psychotic medication | Killaspsy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, careers and advocates.
Prescribed antipsychotic | Schizophrenia | Any antipsychotic medication prescribed | Busch2 | Medicaid Managed Behavioral Health Carve-Outs | Observational retrospective cohort study of ambulatory care Medicaid enrollees in carve-out and comparison regions
Prescribed antipsychotic | Schizophrenia | A first generation antipsychotic medication prescribed | Busch2 | Medicaid Managed Behavioral Health Carve-Outs | Observational retrospective cohort study of ambulatory care Medicaid enrollees in carve-out and comparison regions
Prescribed antipsychotic | Schizophrenia | A second-generation antipsychotic medication (not including clozapine) prescribed | Busch2 | Medicaid Managed Behavioral Health Carve-Outs | Observational retrospective cohort study of ambulatory care Medicaid enrollees in carve-out and comparison regions
Prescribed antipsychotic | Schizophrenia | Prescribed “anti-extrapyramidal symptom” medication, conditional on receiving a first-generation antipsychotic medication | Busch2 | Medicaid Managed Behavioral Health Carve-Outs | Observational retrospective cohort study of ambulatory care Medicaid enrollees in carve-out and comparison regions
Prescribed antipsychotic | Schizophrenia | Clozapine prescribed | Busch2 | Medicaid Managed Behavioral Health Carve-Outs | Observational retrospective cohort study of ambulatory care Medicaid enrollees in carve-out and comparison regions
Prescribed depot antipsychotics | Schizophrenia | Patients with episodic treatment using antipsychotic medication in the study period with a previous history of treatment nonresponse who are receiving depot antipsychotics | Watkins3 | Veteran's Health Administration | Report on developing medical record-based performance indicators to measure the quality of mental health care
Prescribed antipsychotic [Maintenance] | Schizophrenia | Proportion of schizophrenia patients with long-term utilization of antipsychotic medications | Lind4 | New York Medicaid | Report on proposed future measures
Prescribed clozapine | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Number (%) of patients receiving clozapine | Killaspy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.
Prescribed clozapine | Schizophrenia | Number of treatment resistant patients with schizophrenia who were prescribed clozapine. | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia
Prescribed antipsychotic | Schizophrenia | Use of antipsychotic medications for treatment of schizophrenia | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia
Prescribed more than 1 antipsychotic | Psychosis | Median number of prescribed psychotropic medications at discharge (Adapted from the Joint Commission's 2005 Proposed Candidate Core Measure Set for hospital-based, inpatient psychiatric services) | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Prescribed 2 or more antipsychotics | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Number (%) of patients receiving >2 antipsychotic medications | Killaspsy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.
Prescribed 2 or more antipsychotics | Psychosis | Patients discharged on 2 or more antipsychotic medications (Joint Commission: Hospital-Based Inpatient Psychiatric Services (HBIPS) Candidate Core Measure Set) | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Prescribed more than 2 antipsychotics | Schizophrenia | Number of patients with schizophrenia who receive 3 or more antipsychotic medications in a unit of time | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia
Prescribed antipsychotic at right dose | Mental health disorders | Percentage of patients taking antipsychotic receiving dosage within guideline-recommended range | Kilbourne7 | NA | Framework for measuring quality and promoting accountability across silos: the case of mental disorder and co-occurring conditions
Prescribed antipsychotic at right dose | Schizophrenia, inpatient acute care | Is dose within the chlopromazine-equivalent accepted ranges (300-400 mg/day to 1000 mg/day)? | Owen8,9 | Veterans Affairs medical Center, State hospital in southeastern U.S. | Measure derived from schizophrenia guidelines from the Schizophrenia Patient Outcomes Research Team recommendations; and the American Psychiatric Association
Use of antipsychotic medication | Schizophrenia | Beneficiaries with at least one claim for a antipsychotic | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder
Continuity of antipsychotic | Schizophrenia | Number of beneficiaries for whom the total days‟ supply on all nonoverlapping antipsychotic fills was 80 percent or more of the days since their first fill for an antipsychotic | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder
Monitoring for side effects of medication | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Monitoring of therapeutic and side-effects of medication | Killaspsy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.
Maintenance phase medication | Schizophrenia | Percentage of patients receiving an antipsychotic medication for acute symptoms and continued medication for a 12-month period after stabilization of the acute episode | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)
Relapse plan | Schizophrenia | Percentage of stable first-episode patients with a relapse monitoring plan in place after medication discontinuation | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)
Medication management support | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Degree of support given to help patients manage medication | Killaspsy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.

Table D-3 Identified quality measures for psychiatric care in key quality measure databases: Mood stabilizers (antimanic medications)

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Prescribed an antimanic agent | Bipolar Disorder | Percentage of patients with newly diagnosed bipolar disorder who have received at least 1 prescription for a mood-stabilizing agent during the measurement year | NQF Endorsed (0580) Steward: Resolution Health, Inc. | NR | Public Reporting Quality Improvement (Internal to the specific organization)
Use of mood stabilizer | Bipolar Disorder | Use of mood stabilizers (lithium, valproic acid, or carbamazepine) in those with bipolar disorder, acute manic episode | CQAIMH Developer: American Psychiatric Association | AHRQ Level A. Good research-based evidence | NR
Use of mood stabilizer or antimanic agent | Bipolar Disorder | Percentage of patients with Bipolar I Disorder with depressive symptoms and behaviors who have evidence of use of a mood stabilizing or antimanic agent during the first 12 weeks of pharmacotherapy treatment | CQAIMH STABLE Project National Coordinating Council | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Ambulatory/Office-based Care Behavioral Health Care
Use of agent with antimanic properties | Bipolar Disorder | Percentage of patients with Bipolar I Disorder with mania/hypomania, mixed or cycling symptoms and behaviors who have evidence of use of pharmacotherapy agent with antimanic properties during the first 12 weeks of treatment | CQAIMH STABLE Project National Coordinating Council | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement
Registry for those on lithium therapy | Schizophrenia, bipolar or other psychoses | Establishes and maintains a register of patients with schizophrenia, bipolar affective disorder and other psychoses and other patients on lithium therapy | British Medical Association | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement National reporting Pay-for-performance
Prescribed 4 or more psychotropic drugs | Schizophrenia | Discharged from a schizophrenia hospitalization or with two outpatient visits and a primary diagnosis of schizophrenia and prescribed an four or more psychotropic drugs for at least a month during the 12-month period | CQAIMH Developer: Popkin et al., 1998 | AHRQ Level C: Little research evidence, principally based on clinical consensus/ opinion | NR

Table D-4 Identified quality measures for psychiatric care in key quality measure databases: Other medications for SMI (antidepressant, antianxiety, etc.)

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Prescribed an antidepressant | Schizophrenia | Enrollees who had either one inpatient admission or two outpatient visits with a primary diagnosis of schizophrenia within a 12 month period and who received an antidepressant dosage below guideline-recommended thresholds for more than four weeks of the 12-month period. [Amitriptyline, 150mg; Amoxapine, 200mg; Buproprion, 225mg; Clomipramine, 125mg; Desipramine, 150mg; Doxepin, 150mg; Fluoxetine, 20mg; Imipramine, 150mg; Maprotiline, 150mg; Nortriptyline, 75mg; Protriptyline, 30mg; Trazadone, 200mg; Trimipramine, 150mg] | CQAIMH Developer: Popkin et al., 1998 | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Prescribed an antidepressant at discharge | Schizophrenia | Discharged from a schizophrenia hospitalization or with two outpatient visits and a primary diagnosis of schizophrenia and prescribed an antidepressant in the guideline-recommended threshold | CQAIMH Developer: Popkin et al., 1998 | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Prescribed an antidepressant | Bipolar Disorder | Percentage of patients with Bipolar I Disorder symptoms and behaviors who received monotherapy with an antidepressant agent during the first 12 weeks of treatment | CQAIMH STABLE Project National Coordinating Council | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement
Prescribed an antianxiety medication | Schizophrenia | All patients, 18 years of age or older, with a current diagnosis of schizophrenia who report a current diagnosis of anxiety disorder or who have a current chart diagnosis of comorbid anxiety disorder at a specified point in time and who for whom the medical record documents prescription of either a benzodiazepine or propranolol | CQAIMH Developer: Lehman et al., 1998 | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR

Table D-5 Quality measures used in studies for assessing psychiatric outcomes: Mood stabilizers (antimanic medications)

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Use of mood stabilizer medication | Bipolar Disorder | Beneficiaries with at least one claim for lithium, anticonvulsant, or antipsychotic | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder
Prescribed mood stabilizer | Bipolar Disorder | Proportion of patients with bipolar 1 disorder treated with mood stabilizer medications during course of bipolar 1 disorder treatment | Lind4 | New York Medicaid | Report on proposed future measures
Prescribed a mood stabilizer | Bipolar Disorder | Proportion of patients with bipolar disorder experiencing a mild to moderate manic episode who receive monotherapy with lithium, valproate or a second generation antipsychotic such as olanzapine | Duffy12 | NA | Proposed quality of care measures for the treatment of bipolar disorder, based on APA, American Institute for Research and Education and national panel of experts in bipolar disorder and practice guideline development
Prescribed a mood stabilizer | Bipolar Disorder | Proportion of patients with bipolar disorder experiencing a severe manic episode, receiving either lithium, valproate or an antipsychotic | Duffy12 | NA | Proposed quality of care measures for the treatment of bipolar disorder, based on APA, American Institute for Research and Education and national panel of experts in bipolar disorder and practice guideline development
Prescribed a mood stabilizer | Bipolar Disorder | Proportion of patients with bipolar disorder experiencing a mild to moderate mixed episode receiving monotherapy with lithium, valproate or a second generation antipsychotic such as olanzapine | Duffy12 | NA | Proposed quality of care measures for the treatment of bipolar disorder, based on APA, American Institute for Research and Education and national panel of experts in bipolar disorder and practice guideline development
Prescribed a mood stabilizer | Bipolar Disorder | Proportion of patients with bipolar disorder experiencing a severe mixed episode, receiving either valproate and an antipsychotic or lithium and an antipsychotic | Duffy12 | NA | Proposed quality of care measures for the treatment of bipolar disorder, based on APA, American Institute for Research and Education and national panel of experts in bipolar disorder and practice guideline development
Prescribed a mood stabilizer | Bipolar Disorder | Proportion of patients in an acute depressive episode of bipolar disorder receiving either lithium or lamotrigine | Duffy12 | NA | Proposed quality of care measures for the treatment of bipolar disorder, based on APA, American Institute for Research and Education and national panel of experts in bipolar disorder and practice guideline development
Prescribed a mood stabilizer | Bipolar Disorder | Proportion of patients with bipolar disorder who are experiencing rapid cycling, receiving lithium, valproate or as an alternative lamotrigine | Duffy12 | NA | Proposed quality of care measures for the treatment of bipolar disorder, based on APA, American Institute for Research and Education and national panel of experts in bipolar disorder and practice guideline development
Mood stabilizer at optimized dose | Bipolar Disorder | Proportion of patients with bipolar disorder experiencing a manic, mixed or depressive episode during the maintenance phase of treatment (i.e., a “breakthrough episode”), who are receiving an optimized dose of medication compared with the dose used before the onset of breakthrough episode | Duffy12 | NA | Proposed quality of care measures for the treatment of bipolar disorder, based on APA, American Institute for Research and Education and national panel of experts in bipolar disorder and practice guideline development
Psychotropics at discharge | Psychosis | Median number of prescribed psychotropic medications at discharge | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Mood Stabilizer Prescribed [Maintenance] | Bipolar Disorder | Percent of patients included in the study who are in continuous treatment with mood stabilizer medication | Watkins3 | Veteran's Health Administration | Report on developing medical record-based performance indicators to measure the quality of mental health care
Mood Stabilizer Prescribed [Maintenance] | Bipolar Disorder | Percent of patients included in the study who are in intermittent treatment with mood stabilizer medication | Watkins3 | Veteran's Health Administration | Report on developing medical record-based performance indicators to measure the quality of mental health care

Table D-6 Quality measures used in studies for assessing psychiatric outcomes: Other medications for SMI (antidepressant, antianxiety etc.)

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Prescribed an antidepressant | Bipolar Disorder | Proportion of patients with a manic or mixed episode of bipolar disorder, no longer receiving an antidepressant, or who are receiving a lower dose of antidepressants(s) compared with the dose before the onset of the manic or mixed episode | Duffy12 | NA | Proposed quality of care measures for the treatment of bipolar disorder, based on APA, American Institute for Research and Education and national panel of experts in bipolar disorder and practice guideline development

Table D-7 Identified quality measures for psychiatric care in key quality measure databases: Medication adherence

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Adherence to antipsychotic | Schizophrenia, schizo-affective disorder | Percentage of members 19 to 64 years of age with schizophrenia during the measurement year who were dispensed and remained on an antipsychotic medication for at least 80 percent of their treatment period NQF wording: Percentage of individuals 18 years of age or greater as of the beginning of the measurement period with schizophrenia or schizoaffective disorder who are prescribed an antipsychotic medication, with adherence to the antipsychotic medication [defined as a Proportion of Days Covered (PDC)] of at least 0.8 during the measurement period (12 consecutive months) | NCQA NQF ENDORSED (1879) HEDIS | A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Accreditation Decisionmaking by businesses about health plan purchasing Decisionmaking by consumers about health plan/provider choice External oversight/Medicaid External oversight/State government program Internal quality improvement
Noncompliance with antipsychotic prescribed a depot antipsychotic | Schizophrenia | Patients, 18 years of age or older, with a current diagnosis of schizophrenia and a current prescription for antipsychotic medications who report noncompliance with their medication regimen and who are receiving depot antipsychotic medication | CQAIMH Developer: Lehman et al., 1998 | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR

Table D-8 Quality measures used in studies for assessing psychiatric outcomes: Medication adherence

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Continuity of antipsychotic | Schizophrenia | Number of days in measurement year with a an antipsychotic prescription filled Number of patients with a gap in prescription refills | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia
Continuity of medications | Bipolar Disorder | Number of beneficiaries for whom the total days supply on all nonoverlapping lithium, anticonvulsant, or antipsychotic fills was 80 percent or more of the days since their first fill for one of those medications | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder

Table D-9 Identified quality measures for psychiatric care in key quality measure databases: Medication monitoring for side effects and medication levels

Quality of Care Concern | Type of SMI | Quality Measure (process) | Developer | Evidence for Measure | Use of Measure
Follow up visits for medications | Schizophrenia | Patients who had at least 4 medication management or psychotherapy visits with a psychiatrist | CQAIMH Developer: Lehman et al, 1998 | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Blood level monitoring | Bipolar Disorder and other conditions | Number of members enrolled in a health plan, age 18 to 64, with two or more service-based claims for bipolar disorder and at least one claim for Lithium, valproic acid, or carbamazepine in at least three out of four quarters (the same drug in each quarter) of a 12-month period, excluding those individuals who were hospitalized for 30 or more days during the same 12-month period and who have received serum drug level monitoring for a mood stabilizer at least once during a 12 month period | CQAIMH Developer: Marcus et al., 1999 | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Lithium serum medication level measured | Bipolar Disorder | Percentage of patients diagnosed with bipolar disorder and treated with lithium who have evidence of a lithium serum medication level within 12 weeks of beginning treatment | CQAIMH STABLE Project National Coordinating Council | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement
Lithium at right dosage | Schizophrenia, bipolar or other psychoses | Percentage of patients on lithium therapy with a record of lithium levels in therapeutic range in the preceding 4 months | British Medical Association | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Internal quality improvement National reporting Pay-for-performance
Symptom monitoring | Schizophrenia | Proportion of patients who have neurologic side effects | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research
Symptom monitoring | Schizophrenia | Proportion of patients who have sexual side effects | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research
Symptom monitoring | Schizophrenia | Proportion of patients who have sleeping and sedation side effects | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research
Symptom monitoring | Schizophrenia | Proportion of patients who have weight gain as a side effect | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research
Symptom monitoring | Bipolar Disorder | Percentage of patients diagnosed with bipolar disorder and treated with an antipsychotic agent who were assessed for the presence of extrapyramidal symptoms twice within the first 24 weeks of treatment | CQAIMH STABLE Project National Coordinating Council | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement
Side effect monitoring | Bipolar Disorder and other conditions | Number of members enrolled in a health plan, age 18 to 64, with two or more service-based claims for bipolar disorder and at least one claim for Lithium, valproic acid, or carbamazepine in at least three out of four quarters (the same drug in each quarter) of a 12-month period, excluding those individuals who were hospitalized for 30 or more days during the same 12-month period and who have undergone complete blood count (valproate/carbamazepine), liver (valproate/carbamazepine), thyroid and renal function testing (Lithium) at least once in the 12 month period | CQAIMH Developer: Marcus et al., 1999 | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Medication dosage change due to symptoms | Schizophrenia, schizo-affective disorder | Consumers with akathisia and extrapyramidal symptoms who have one of the following: reduction in antipsychotic dose, switch to different antipsychotic, addition of a beta blocker, benzodiazepines, anticholinergic, or antiparkinson; or offered an atypical antipsychotic | CQAIMH Developer: Young et al, 1998 | AHRQ Level A. Good research-based evidence | NR
Treatment of drug-related EPS | Schizophrenia | Patients, 18 years of age or older, with a diagnosis of schizophrenia receiving antipsychotic medication who report on a survey that they experience extrapyramidal symptoms and who have received a prescription for an anti-Parkinson medication | CQAIMH Developer: Lehman et al., 1998 | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Treatment of tardive dyskinesia | Schizophrenia | Consumers, between the ages of 18 and 65, with a diagnosis of schizophrenia or schizoaffective disorder who have been in treatment for at least 3 months, spent nor more than 21 days in the hospital during the previous 3 months, have had at least 1 visit with a psychiatrist during the 3 month period and have significant TD as indicated by the Abnormal Involuntary Movement Scale and who had a reduction in antipsychotic dosage during the 3-month period or have been offered treatment with clozapine | CQAIMH Developer: Young et al., 1998 | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Medication change due to psychotic symptoms | Schizophrenia or schizoaffective disorder | Patients who have had at least 1 visit with a psychiatrist and no more than 21 days in the hospital, and have had significant psychotic symptoms based on Brief Psychiatric Rating Scale, and who have had a change in antipsychotic drug or dosage or were offered treatment with clozapine | CQAIMH Developer: Young et al, 1998 | AHRQ Level A. Good research-based evidence | NR

Table D-10 Quality measures used in studies for assessing psychiatric outcomes: Medication monitoring for side effects and medication levels

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Lithium blood levels | Schizophrenia, bipolar disorder | Beneficiaries with at least one claim during the study period for lithium level screening | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder
Anticonvulsant blood levels | Schizophrenia, bipolar disorder | Beneficiaries with at least one claim during the study period for valproate or carbamazepine level screening | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder
Side effect monitoring | Schizophrenia | Percentage of patients on antipsychotic medication evaluated for side effects | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)
Side effect monitoring | Bipolar Disorder | Percent of patients in a new treatment episode with assessment of medication side effects (weight/BMI, akathesia) 2–4 months following the initiation of an antipsychotic or mood stabilizer | Watkins3 | Veteran's Health Administration | Report on developing medical record-based performance indicators to measure the quality of mental health care
Extrapyramidal symptoms | Bipolar Disorder | Record side effects from medications (monitor extrapyramidal symptoms) | Kilbourne13 used STABLE Project National Coordinating Council, RAND and APA measures | Veteran's Health Administration | Cross-sectional, cumulative data to 2 years prior to assessment
Extrapyramidal symptoms | Schizophrenia | Percentage of patients with extrapyramidal side effects who receive treatment for extrapyramidal symptoms | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)
Monitoring for side effects | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Monitoring of therapeutic and side-effects of medication | Killaspy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.

Table D-11 Quality measures used in studies for assessing psychiatric outcomes: Symptom and function monitoring

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Symptom monitoring | Bipolar Disorder | Percentage of patients diagnosed and treated for bipolar disorder who are monitored for change in their symptom complex within 12 weeks of initiating treatment | CQAIMH STABLE Project National Coordinating Council | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement
Function monitoring | Bipolar Disorder | NQF: Percentage of patients treated for bipolar disorder with evidence of level-of-function evaluation at the time of the initial assessment and again within 12 weeks of initiating treatment CQAIMH: Percentage of patients diagnosed and treated for bipolar disorder who are monitored for change in their level-of-functioning in response to treatment within 12 weeks of initiating treatment Patients monitored for change in their level-of-functioning in response to treatment | CQAIMH STABLE Project National Coordinating Council NQF ENDORSED (0112) | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Public Reporting Quality Improvement (Internal to the specific organization), Quality Improvement with Benchmarking (external benchmarking to multiple organizations), Regulatory and Accreditation Programs

Table D-12 Quality measures used in studies for assessing psychiatric outcomes: Symptom and function monitoring

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Symptom monitoring | Bipolar Disorder | Monitored for change in their symptom complex (assess psychotic, hallucinatory and delusional symptoms) | Kilbourne13 used STABLE Project National Coordinating Council measure | Veteran's Health Administration | Cross-sectional, cumulative data to 2 years prior to assessment

Table D-13 Identified quality measures for psychiatric care in key quality measure databases: Screening for risk of suicide

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Risk of violence to self and others | Hospital-based inpatient psychiatric services (all age groups but can separate out adults) | Percentage of patients admitted to a hospital-based inpatient psychiatric setting who are screened within the first three days of admission for all of the following: risk of violence to self or others, substance use, psychological trauma history and patient strengths | Joint Commission (Core Measure) NQMC: 007527 | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Accreditation Collaborative inter-organizational quality improvement Internal quality improvement
Risk of suicide | Bipolar Disorder | Percentage of patients with bipolar disorder with evidence of an initial assessment that includes an appraisal for risk of suicide | CQAIMH STABLE Project National Coordinating Council NQF ENDORSED (0111) | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Public Reporting Quality Improvement (Internal to the specific organization) Quality Improvement with Benchmarking (external benchmarking to multiple organizations) Regulatory and Accreditation Programs
Risk of suicide | Schizophrenia | Proportion of hospitalized patients assessed for suicide risk (documented in patient record) at discharge | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research

Table D-14 Quality measures used in studies for assessing psychiatric outcomes: Screening for risk of suicide

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Suicide risk | Bipolar Disorder | Assess suicidal ideation | Kilbourne13 used STABLE Project and APA guidelines | Veteran's Health Administration | Cross-sectional, cumulative data to 2 years prior to assessment
Suicide rate | Schizophrenia | Number of suicides divided by number of patient-treated years Number of suicide attempts divided by number of patient-treated years | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)

Table D-15 Identified quality measures for psychiatric care in key quality measure databases: Co-occurring substance use

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Substance use | Schizophrenia | Patients admitted to a hospital whose inpatient admission or discharge assessment indicates the presence of a recent (< 30 days) history of substance abuse or dependence and includes a referral to substance abuse treatment or documentation that the patient refused substance abuse treatment | CQAIMH (Dickey et al, in press) | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Alcohol use | Schizophrenia, bipolar or other psychoses | Percentage of patients with schizophrenia, bipolar affective disorder and other psychoses who have a record of alcohol consumption in the preceding 12 months | British Medical Association | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement National reporting Pay-for-performance
Alcohol and chemical substance use | Bipolar Disorder | Percentage of patients with depression or bipolar disorder with evidence of an initial assessment that includes an appraisal for alcohol and chemical substance use CMS: Bipolar disorder and major depression: Appraisal for alcohol or chemical substance use. | CQAIMH STABLE Project National Coordinating Council NQF ENDORSED (0110) NQMC:003493 HHS:004910 | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Public Reporting Quality Improvement (Internal to the specific organization) Quality Improvement with Benchmarking (external benchmarking to multiple organizations) Regulatory and Accreditation Programs Pay-for-reporting
Substance use | Hospital-based inpatient psychiatric services (all age groups but can separate out adults) | Percentage of patients admitted to a hospital-based inpatient psychiatric setting who are screened within the first three days of admission for all of the following: risk of violence to self or others, substance use, psychological trauma history and patient strengths | Joint Commission (Core Measure) NQMC: 007527 | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Accreditation Collaborative inter-organizational quality improvement Internal quality improvement

Table D-16 Quality measures used in studies for assessing psychiatric outcomes: Co-occurring substance use

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Illicit drug use | Bipolar Disorder | Assess illicit drug use | Kilbourne13 Used STABLE Project and RAND measures | Veteran's Health Administration | Cross-sectional, cumulative data to 2 years prior to assessment
Alcohol use | Bipolar Disorder | Assess alcohol use | Kilbourne13 Used STABLE Project and RAND measures | Veteran's Health Administration | Cross-sectional, cumulative data to 2 years prior to assessment
Drug and alcohol screening | Psychosis | Drug and alcohol abuse screening at the initial evaluation for psychiatric disorder | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Substance use screening | Mental health disorders | Percentage of patients in mental health programme have documented substance use screening | Kilbourne7 | NA | Framework for measuring quality and promoting accountability across silos: the case of mental disorder and co-occurring conditions
Substance use | Schizophrenia | Percentage of patients admitted with a diagnosis of schizophrenia receiving an assessment of substance misuse | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)
Substance use screening or counseling service | Schizophrenia | Patients with schizophrenia who have co-occurring substance use disorder who receive a screening or counseling service for substance use disorder in the measurement year | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia
Drug and alcohol detailed assessment | Psychosis | Detailed assessment of drug and alcohol abuse if screening positive for drug/alcohol use | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Alcohol and chemical substance use | Bipolar Disorder | Percent of patients with a new treatment episode with initial assessment that includes appraisal for alcohol and chemical substance use | Watkins3 | Veteran's Health Administration | Report on developing medical record-based performance indicators to measure the quality of mental health care
Substance abuse assessment | Schizophrenia, Bipolar, MDD, Substance use disorder, PTSD | Assessment of substance use disorder, trauma, and patient strengths completed for inpatients whose first hospitalization of the study period: (1) Presence of co-occurring substance use disorder (Not Included in Substance Use Disorder Diagnosis) and (2) History of psychological trauma and contribution of trauma to current presentation (Not Included in PTSD Diagnosis) and (3) Patient strengths | Watkins3 | Veterans Health Administration | Report on developing medical record-based performance indicators to measure the quality of mental health care
Substance use program | Mental health disorders | Percentage of patients in substance use programme engaged in care (e.g., two outpatient visits within 14 days) | Kilbourne7 | NA | Framework for measuring quality and promoting accountability across silos: the case of mental disorder and co-occurring conditions
Treatment plan for substance abuse | Psychosis | A treatment plan that reflects substance abuse treatment goals | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Aftercare plan for substance abuse | Psychosis | An aftercare plan that addresses substance use/abuse | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Tobacco use | Bipolar Disorder | Assess tobacco use | Kilbourne13 used RAND measures | Veteran's Health Administration | Cross-sectional, cumulative data to 2 years prior to assessment

Table D-17 Identified quality measures for psychiatric care in key quality measure databases: Comorbid depression and anxiety, PTSD

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Assessed for depression prior to treatment | Bipolar and Major Depression | Percentage of patients presenting with depression who were assessed, prior to the initiation of treatment, for the presence of prior or current symptoms and/or behaviors associated with mania or hypomania | CQAIMH STABLE Project National Coordinating Council NQF ENDORSED (0109) | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Public Reporting Quality Improvement (Internal to the specific organization) Quality Improvement with Benchmarking (external benchmarking to multiple organizations) Regulatory and Accreditation Programs

Table D-18 Quality measures used in studies for assessing psychiatric outcomes: Comorbid depression and anxiety, PTSD

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Assessment of depression | Schizophrenia | Percentage of patients receiving an assessment of depressive symptoms at intake (as measured with a structured scale) | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)
PTSD | Bipolar Disorder | Assess PTSD | Kilbourne13 used RAND measures | Veteran's Health Administration | Cross-sectional, cumulative data to 2 years prior to assessment

Table D-19 Identified quality measures for psychiatric care in key quality measure databases: Early detection, lack of treatment

Quality of Care Concern | Type of SMI | Quality Measure (process) | Developer | Evidence for Measure | Use of Measure
Lack of treatment | Schizophrenia | Duration of untreated psychosis before treatment | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research

Table D-20 Quality measures used in studies for assessing psychiatric outcomes: Early detection, lack of treatment

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Early detection of psychotic symptoms | Schizophrenia | Percentage of individuals with first-episode psychosis detected within 6 months of onset of psychotic symptoms | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)
Early detection of SMI | Schizophrenia, paranoid and other psychoses, organic brain syndrome, or major affective disorder (meeting disability and duration criteria) | In-patient admission on detection of SMI | Charlwood14 | NA | Report on the development and final recommendations for outcome indicators for severe mental illness for the UK from their National Centre for Health Outcomes Development
Lost-to followup | Schizophrenia, paranoid and other psychoses, organic brain syndrome, or major affective disorder (meeting disability and duration criteria) | Proportion of people with SMI lost to followup by specialist services | Charlwood14 | NA | Report on the development and final recommendations for outcome indicators for severe mental illness for the UK from their National Centre for Health Outcomes Development
Patients no longer in treatment | Bipolar Disorder | Percent of patients included in the study who are lost to followup or leave treatment against medical advice | Watkins3 | Veteran's Health Administration | Report on developing medical record-based performance indicators to measure the quality of mental health care

Table D-21 Identified quality measures for psychiatric care in key quality measure databases: Assessment for psychopathy and cognitive functioning

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Psychopathy exam | Schizophrenia | Proportion of incident (diagnosed within 12 months of contact) patients examined for psychopathology by a medical specialist | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research
Use of diagnostic instruments for assessment | Schizophrenia | Proportion of incident (diagnosed within 12 months of contact) patients examined for psychopathology by a specialist where the assessment is done using a diagnostic instrument (SCAN, OPCRIT, SCID) | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research
Cognitive function | Schizophrenia | Proportion of incident (diagnosed within 12 months of contact) patients for which cognitive function was examined by a psychologist | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research

Table D-22 Quality measures used in studies for assessing psychiatric outcomes: Assessment for psychopathy and cognitive functioning

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
NO STUDIES

Table D-23 Identified quality measures for psychiatric care in key quality measure databases: Outpatient followup

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Outpatient visit | Schizophrenia | Proportion of patients discharged to an outpatient program | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Care Coordination Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research
Discharged to an outpatient program | Schizophrenia | Proportion of patients discharged to an outpatient program for whom an outpatients' visit is registered within 6 months of discharge | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research
Followup within 7. 30 days of discharge | Hospitalization for mental illness | Followup after hospitalization for mental illness for those 6 years of age and older and who had an outpatient visit, an intensive outpatient encounter, or partial hospitalization with a mental health practitioner within; - 7 days of discharge; - 30 days of discharge.; NOTE THIS NQF: 1937 Not in use, (Public Reporting, Quality Improvement with Benchmarking (external benchmarking to multiple organizations) The percentage of discharges for individuals 18 – 64 years of age who were hospitalized for treatment of schizophrenia and who had an outpatient visit, an intensive outpatient encounter or partial hospitalization with a mental health practitioner. Two rates are reported.; - The percentage of individuals who received followup within 30 days of discharge; The percentage of individuals who received followup within 7 days of discharge | NCQA NQF ENDORSED (0576) [HEDIS is for mental illness not just SMI] | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Decisionmaking by businesses about health plan purchasing Decisionmaking by consumers about health plan/provider choice External oversight/Medicaid External oversight/Medicare External oversight/State government program Internal quality improvement
Discharged with outpatient visits | Schizophrenia | Discharged with outpatient visits | CQAIMH (Fischer and Owen) | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Adjunctive psychosocial intervention | Bipolar Disorder | Percentage of patients with bipolar disorder who receive a recommendation for an adjunctive psychosocial intervention, including evidence-based therapies, within 12 weeks of initiating treatment | CQAIMH STABLE Project National Coordinating Council | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement

Table D-24 Quality measures used in studies for assessing psychiatric outcomes: Outpatient followup

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Followup after hospitalization | Psychiatric hospitalization for Mental illness | HEDIS: 7 day followup after discharge | Druss15 | US HMO data | Using data from US HMOs participating in the HEDIS, analyzed the associate between five HEDIS measures of mental health performance, 2 of which are for followup after psychiatric hospitalization
Followup after hospitalization | Psychiatric hospitalization for Mental illness | HEDIS: 30 days followup after discharge | Druss15 | US HMO data | Using data from US HMOs participating in the HEDIS, analyzed the associate between five HEDIS measures of mental health performance, 2 of which are for followup after psychiatric hospitalization
Followup after hospitalization | Psychiatric hospitalization for Mental Illness | Followup after hospitalization for mental illness | Lind4 | New York Medicaid | Report on proposed future measure, stated that this measure is in current use in New York Medicaid system
Followup after hospitalization | Schizophrenia | Community followup after hospitalization within 1 to 7 days | Plever16 | Queensland, Australia Mental Health Services | Study examined the lump sum payments tied to this quality indicator
Followup after hospitalization | Schizophrenia | Percentage of hospital separations for individuals with a diagnosis of schizophrenia who receive at least 1 psychiatry service or physician contact within 30 days of discharge | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)
Followup after hospitalization | Schizophrenia | Patients with schizophrenia discharged from the hospital who receive a followup visit within a specified time interval | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia
Followup appointment after discharge | Psychosis | Followup appointment for mental illness scheduled within 7 days of discharge | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Followup after no-show visit | Bipolar Disorder | Follow up with patient after a no-show visit (enhance treatment experience) | Kilbourne13 used STABLE Project National Coordinating Council, RAND and APA measures | Veteran's Health Administration | Cross-sectional, cumulative data to 2 years prior to assessment
Assertive Community Treatment post hospitalization | Schizophrenia | Patients with schizophrenia who were recently discharged from an inpatient setting who receive ACT | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia
Assertive Community Treatment | Schizophrenia, bipolar disorder | Beneficiaries with at least one ACT claim during the study period | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder
Psychosocial treatment | Schizophrenia | Patients with schizophrenia who received psychosocial treatment during the measurement year | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia
Evidence-based psycho-social treatment | Schizophrenia, bipolar disorder | Beneficiaries with at least one claim for psychotherapy, family therapy, supported employment or ACT during the study period | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder
Any psychosocial service | Schizophrenia, bipolar disorder | Beneficiaries with at least one claim for and ambulatory mental health service other than evaluation, testing, or medication management during the study period | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder
Combination of medication and Psychosocial treatment | Schizophrenia | Patients with schizophrenia receiving both medication and psychosocial treatment during the measurement year | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia

Table D-25 Identified quality measures for psychiatric care in key quality measure databases: Care plans and continuity (treatment engagement)

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure of Measure
Care plan created | Hospital-based inpatient psychiatric services (all ages but adults can be separated out) | Percentage of patients discharged from a hospital-based inpatient psychiatric setting with a continuing care plan created CMS: Post discharge continuing care plan created. Also added: “and contains all of the following: reason for hospitalization, principal discharge diagnosis, discharge medications and next level of care recommendations” | Joint Commission (Core Measure) NQF ENDORSED (0557) NQMC: 007528 HBIPS-6 HHS: 004858 | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Accreditation Care Coordination Collaborative inter-organizational quality improvement Public reporting
Care plan provided to next level of care | Hospital-based inpatient psychiatric services (all ages but adults can be separated out) | Discharged from hospital-based psychiatric inpatient setting with a continuing care plan provided to the next level of care clinician or entity CMS: Post discharge continuing care plan transmitted to next level of care provider upon discharge | Joint Commission (Core Measure) NQF ENDORSED (0558) NQMC: 007529 HBIPS-7 HHS: 004857 | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Accreditation Care coordination Collaborative inter-organizational quality improvement Internal quality improvement Public reporting
Second visit due to exacerbation | Schizophrenia | Patients with an exacerbation (no encounters in prior 90 days who received a second psychiatric service (outpatient visit with MD, or DO, or ARNP or PA, or inpatient visit or detox, observation/hold bed, residential, partial hospitalization | CQAIMH (Value Options) | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Terminated treatment by patient | Schizophrenia | Patients with one inpatient admission or two outpatient visits who terminated treatment or were lost to followup (cessation of patient-provider contact due to known or unknown causes, excluding patient death) | CQAIMH Popkin et al., 1998 | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Outpatient visits assigned a primary care provider | Schizophrenia | Patients with one inpatient admission or two outpatient visits who were assigned a primary care provider | CQAIMH Popkin et al., 1998 | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR
Enrolled in ACT | Schizophrenia | Patients with two or more inpatient stays or four emergency room crisis visits who are enrolled in a Program for Assertive Community Treatment | CQAIMH Developer: American Psychiatric Association | AHRQ Level A. Good research based evidence | NR
Relapse monitoring plan | Schizophrenia | Patients in stable phase and discontinued from antipsychotic with a relapse-monitoring plan designed for use in recognizing and responding to early signs of new episode | CQAIMH Developer: American Psychiatric Association | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion | NR

Table D-26 Quality measures used in studies for assessing psychiatric outcomes: Care plans and continuity (treatment engagement)

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Notification to outpatient mental health provider | Psychosis | Notification of the patient's hospitalization to the outpatient mental health provider | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Notification to outpatient mental health provider within 2 days of admission | Psychosis | Notification of the patient's hospitalization to the outpatient mental health provider within 2 days of admission | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Notification to outpatient mental health provider or primary care provider to obtain information | Psychosis | Collaboration with the outpatient mental health provider and/or primary care physician in order to obtain information regarding the patient's past psychiatric and/or medical history to develop common treatment goals and discharge plans | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Notification to outpatient mental health provider or primary care provider within 2 days of admission | Psychosis | Collaboration with the outpatient mental health provider and/or primary care physician within 2 days of admission | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Discharge plans to community health providers | Psychosis | Communication of discharge recommendations to the community health providers | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Discharge from followup | Schizophrenia, paranoid and other psychoses, organic brain syndrome, or major affective disorder (meeting disability and duration criteria) | Proportion of people with SMI discharged from followup by specialist services | Charlwood14 | NA | Report on the development and final recommendations for outcome indicators for severe mental illness for the UK from their National Centre for Health Outcomes Development
Patient involvement in treatment | Psychosis | Patient involvement in treatment defined as documentation that included one or more of the following ways of participating in the treatment process:; - Attendance and involvement in staffing; - Patient identification of their problems; - Patient identification of their goals for this hospitalization; - Patient identification of their strengths and weaknesses; - Patient identification of coping strategies; - Patient indicating agreement with their treatment plan | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Patient engagement in care | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Degree of patients' influence and involvement in choice of medication and dose | Killaspy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.
Healthy therapeutic alliance between patient and provider | Schizophrenia | Providers who work in partnership with patients and family members, offering help, treatment, and care in an atmosphere of hope and optimism (taking time to build a supportive and empathetic relationship with patients and family members) | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services ( 36 essential measures)
Case management | Schizophrenia | Percentage of individuals assigned a case manager on admission to the schizophrenia treatment service | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)
Case management | Schizophrenia | Patients with schizophrenia who were recently discharged from an inpatient setting who received case management during the measurement year | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia
Relapse Monitoring Plan | Bipolar Disorder | Percent of patients included in the study who are not on mood stabilizer medication but have mental health provider visits with a documented relapse monitoring plan | Watkins3 | Veteran's Health Administration | Report on developing medical record-based performance indicators to measure the quality of mental health care
Case management for those with low-level functioning | Bipolar Disorder | Percent of patients included in the study with a GAF score ≤40 and 4 or more visits with a case manager during study period | Watkins3 | Veteran's Health Administration | Report on developing medical record-based performance indicators to measure the quality of mental health care
Case management for those with low-level functioning | Schizophrenia | Percent of patients included in the study with a GAF score ≤40 visits with a case manager during study period | Watkins3 | Veteran's Health Administration | Report on developing medical record-based performance indicators to measure the quality of mental health care

Table D-27 Identified quality measures for psychiatric care in key quality measure databases: Readmissions

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Readmission rate | Schizophrenia, delusional and non-organic psychotic disorders; mood/affective disorders; but also substance-related disorders; anxiety disorders; and selected disorders of adult personality and behavior | Risk adjusted percentage of individuals who had three or more episodes of care for a selected mental illness over all those who had at least one episode of care for a selected mental illness in general hospitals within a given year | Canadian Institute for Health Information | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement National health policymaking National reporting State/Provincial health policymaking
Readmission | Schizophrenia, delusional and non-organic psychotic disorders; mood/affective disorders; but also substance-related disorders; anxiety disorders; and selected disorders of adult personality and behavior | Risk adjusted rate of readmission following discharge for a mental illness | Canadian Institute for Health Information | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Decisionmaking by managers about resource allocation Internal quality improvement National health policymaking National reporting State/Provincial health policymaking

Table D-28 Quality measures used in studies for assessing psychiatric outcomes: Readmissions

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Readmission rates | Schizophrenia | Total number of acute-care psychiatric admissions among schizophrenia treatment service patients that occurred within 30 days of discharge divided by the total number of acute-care psychiatric discharges of schizophrenia treatment service patients per year. | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)
Readmission | Schizophrenia, paranoid and other psychoses, organic brain syndrome, or major affective disorder (meeting disability and duration criteria) | Hospital readmission frequencies for a resident population of people with SMI | Charlwood14 | NA | Report on the development and final recommendations for outcome indicators for severe mental illness for the UK from their National Centre for Health Outcomes Development
Emergency Department psychiatric revisits | Severe and persistent mental illness | Psychiatric revisits to Emergency Department | Adams17 | Local hospital Emergency Department | Based on the expectation that Readmission rates are to be one of the quality measures to be implemented, they implemented a quality improvement process in their Emergency Department to reduce psychiatric revisits. 80% of their hospital psychiatric admissions come through their Emergency Department. Their QI program decreased mean psychiatric emergency revisit rates.

Table D-29 Identified quality measures for psychiatric care in key quality measure databases: Inpatient stay characteristics

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Rate of discharge | Schizophrenia, delusional and non-organic psychotic disorders; mood/affective disorders; but also substance-related disorders; anxiety disorders; and selected disorders of adult personality and behavior | Age-standardized rate of separations from general hospitals through discharge or death following a hospitalization for a selected mental illness, per 100,000 population | Canadian Institute for Health Information | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Monitoring and planning Monitoring health state(s) National health policymaking National reporting State/Provincial health policymaking
Days of hospitalization | Schizophrenia, delusional and non-organic psychotic disorders; mood/affective disorders; but also substance-related disorders; anxiety disorders; and selected disorders of adult personality and behavior | Age-adjusted rate of total number of days in general hospitals for selected mental illness, per 10,000 population | Canadian Institute for Health Information | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Monitoring and planning Monitoring health state(s) National health policymaking National reporting State/Provincial health policymaking

Table D-30 Quality measures used in Studies for assessing medical outcomes: Inpatient stay characteristics

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
No studies??

Table D-31 Identified quality measures for psychiatric care in key quality measure databases: Restraints

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Seclusion | Hospital–based inpatient psychiatric services (all age groups but adults can be separated) | Total number of hours that all patients admitted to a hospital-based inpatient psychiatric setting were held in seclusion CMS: Hours of seclusion | Joint Commission NQF ENDORSED (0641) NGCM: 007525 HBIPS-3 HHS: 004854 | One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Accreditation Collaborative inter-organizational quality improvement Internal quality improvement Public reporting
Physical restraint | Hospital-based inpatient psychiatric services (all age groups but adults can be separated) | Total number of hours that all patients admitted to a hospital-based inpatient psychiatric setting were maintained in physical restraint CMS: Hours of physical restraint use | Joint Commission NQF ENDORSED (0640) NGCM: 007525 HBIP-3 HHS: 004853 | One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Accreditation Collaborative inter-organizational quality improvement Internal quality improvement Public reporting

Table D-32 Quality measures used in studies for assessing psychiatric outcomes: Restraints

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Restraint/seclusion | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Number of episodes of restraint/seclusion in past 3 months | Killaspy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.

Table D-33 Identified quality measures for patient-centered care in key quality measure databases: Psychoeducation and psychotherapy

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Psycho-education | Schizophrenia | Patients with either one inpatient admission or two outpatient visits who received education about their prescribed medications and side effects | CQAIMH Developer: Popkin et al 1998 | AHRQ Level C. Little research evidence, principally based on clinical consensus/opinion | NR
Psycho-education | Schizophrenia | Proportion of incident (diagnosed within 12 months of contact) patients receiving psychoeducation via a manualized course within 2 years of discharge | The Danish National Schizophrenia Registry | A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research
Psycho-education | Bipolar Disorder | Percentage of patients diagnosed and treated for bipolar disorder who are provided with education and information about their illness and treatment within 12 weeks of initiating treatment | CQAIMH STABLE Project National Coordinating Council | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement

Table D-34 Quality measures used in Studies for assessing patient-centered outcomes: Psychoeducation and psychotherapy

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Psycho-education | Schizophrenia | Percentage of patients formal education regarding psychosis (psychoeducation either in group or individually) | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)
Psycho-education approach | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Whether unit uses written information/groups/expert talks to help with psychoeducation | Killaspy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.
Individual Therapy | Schizophrenia | Individual therapy | Busch2 | Medicaid Managed Behavioral Health Carve-Outs | Observational retrospective cohort study of ambulatory care Medicaid enrollees in carve-out and comparison regions
Group Therapy | Schizophrenia | Group therapy | Busch2 | Medicaid Managed Behavioral Health Carve-Outs | Observational retrospective cohort study of ambulatory care Medicaid enrollees in carve-out and comparison regions
Psychotherapy | Schizophrenia, bipolar disorder | Beneficiaries with at least one psychotherapy claim during the study period | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder

Table D-35 Identified quality measures for medical care in key quality measure databases: Diabetes and weight gain

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Screening for diabetes | Bipolar Disorder | Percentage of patients diagnosed with bipolar disorder and treated with an atypical antipsychotic agent who receive at least one screening for hyperglycemia within the initial 16 weeks of treatment | CQAIMH STABLE Project National Coordinating Council NQF ENDORSED (0003) | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Public Reporting Quality Improvement (Internal to the specific organization) Quality Improvement with Benchmarking (external benchmarking to multiple organizations) Internal Quality Improvement
Screening for diabetes | Schizophrenia, Bipolar Disorder | Diabetes screening for people with schizophrenia or bipolar disorder who are using antipsychotic medications: percentage of members 18 to 64 years of age with schizophrenia or bipolar disorder who were dispensed an antipsychotic medication and had a diabetes screening test during the measurement year. | NCQA NQMC– update pending CQAIMH STABLE Project National Coordinating Council NQF ENDORSED (1932) HEDIS | A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Accreditation Decisionmaking by businesses about health plan purchasing Decisionmaking by consumers about health plan/provider choice External oversight/Medicaid External oversight/State government program Internal quality improvement
Screening for hyperglycemia | Schizophrenia | Proportion of patients who have an increased blood glucose level | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research
Diabetes monitoring | Schizophrenia | Diabetes monitoring for people with diabetes and schizophrenia: percentage of members 18 to 64 years of age with schizophrenia and diabetes who had both an LDL-C test and an HbA1c test during the measurement year | NCQA NGCM- update pending NQF ENDORSED (1934) HEDIS | | Consensus studies Accreditation Decisionmaking by businesses about health plan purchasing Decisionmaking by consumers about health plan/provider choice External oversight/Medicaid External oversight/State government program Internal quality improvement
Screening for diabetes | Schizophrenia, bipolar or other psychoses | Percentage of patients aged 40 years or over with schizophrenia, bipolar affective disorder and other psychoses who have a record of blood glucose or HbA1c in the preceding 12 months | British Medical Association | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement National reporting Pay-for-performance
Screening for diabetes | Bipolar Disorder | Percentage of patients diagnosed with bipolar disorder and treated with an atypical antipsychotic agent who receive at least one screening for hyperglycemia within the initial 16 weeks of treatment | CQAIMH STABLE Project National Coordinating Council | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement
Screening for weight gain | Schizophrenia, bipolar or other psychoses | Percentage of patients with schizophrenia, bipolar affective disorder and other psychoses who have a record of BMI in the preceding 12 months | British Medical Association | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement National reporting Pay-for-performance
Screening for weight gain | Schizophrenia | Proportion of patients who have an increased body mass index (BMI) | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research
Screening for weight gain | Bipolar | Percentage of patients with bipolar disorder who were monitored for weight gain during initial 12 week period of treatment | CQAIMH STABLE Project National Coordinating Council | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement
Waist circumference | Schizophrenia | Proportion of patients who have an increased measure of abdominal waistline | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research

Table D-36 Quality measures used in studies for assessing medical outcomes: Diabetes and weight gain

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Blood glucose | Community psychiatric patients prescribed antipsychotics | All patients prescribed continuing antipsychotic medication should have their blood glucose (random or fasting sample, or HbA1c) measured at least once per year | Barnes18 | UK National Health Service secondary care mental health Trusts | Baseline and one year followup audit against evidence based standards for metabolic syndrome
Blood glucose | Mental health disorders | Percentage of patients initiating a second generation antipsychotic with fasting glucose recorded 12 weeks and 6 months | Kilbourne7 | NA | Framework for measuring quality and promoting accountability across silos: the case of mental disorder and co-occurring conditions
Diabetes screening | Schizophrenia, bipolar disorder | Beneficiaries with at least one claim during the study period for a glucose test | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder
Eye and foot exams | Mental health disorders | Percentage of patients with diabetes who receive annual eye and foot exams | Kilbourne7 | NA | Framework for measuring quality and promoting accountability across silos: the case of mental disorder and co-occurring conditions
Weight | Bipolar Disorder | Record weight | Kilbourne13 used RAND measures | Veteran's Health Administration | Cross-sectional, cumulative data to 2 years prior to assessment
Weight gain | Bipolar Disorder | Monitor for weight gain | Kilbourne13 used STABLE project and RAND measures | Veteran's Health Administration | Cross-sectional, cumulative data to 2 years prior to assessment
Weight assessment/ counseling | Schizophrenia | Patients with schizophrenia who have received a prescription for an antipsychotic medication, and who have evidence of weight assessment or counseling | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia
BMI (or waist circumference) | Community psychiatric patients prescribed antipsychotics | All patients prescribed continuing antipsychotic medication should have their body mass index (or other measure of obesity such as waist circumference) measured at least once per year | Barnes18 | UK National Health Service secondary care mental health Trusts | Baseline and one year followup audit against evidence based standards for metabolic syndrome

Table D-37 Identified quality measures for medical care in key quality measure databases: Hypertension

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Blood pressure | Schizophrenia | Proportion of patients who have an increased blood pressure | The Danish National Schizophrenia Registry | A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research
Blood pressure | Schizophrenia, bipolar or other psychoses | Percentage of patients with schizophrenia, bipolar affective disorder and other psychoses who have a record of blood pressure in the preceding 12 months | British Medical Association | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement National reporting Pay-for-performance
Blood pressure | Bipolar Disorder | Blood pressure measurement | CQAIMH STABLE Project National Coordinating Council | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement

Table D-38 Quality measures used in studies for assessing medical outcomes: Hypertension

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Blood Pressure | Bipolar Disorder | Record blood pressure | Kilbourne13 used RAND measures | Veteran's Health Administration | Cross-sectional, cumulative data to 2 years prior to assessment
Blood Pressure | Community psychiatric patients prescribed antipsychotics | All patients prescribed continuing antipsychotic medication should have their blood pressure measured at least once per year | Barnes18 | UK National Health Service secondary care mental health Trusts | Baseline and one year followup audit against evidence based standards for metabolic syndrome
Blood pressure | Schizophrenia | Patients with schizophrenia who receive a blood pressure screening | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia

Table D-39 Identified quality measures for medical care in key quality measure databases: Cardiovascular disease

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
LDL-C test for those with CVD | Schizophrenia | Cardiovascular monitoring for people with cardiovascular disease and schizophrenia: percentage of members 18 to 64 years of age with schizophrenia and cardiovascular disease who had an LDL-C test during the measurement year NQF: percentage of patients 18–64 years of age with schizophrenia and cardiovascular disease, who had an LDL-C test during the measurement year NQF: 1927 Not in use, Public Reporting, Quality Improvement (Internal to the specific organization) Percentage of individuals 25 to 64 years of age with schizophrenia or bipolar disorder who were prescribed any antipsychotic medication and who received a cardiovascular health screening during the measurement year | NCQA NQMC: Update pending NQF ENDORSED (1933) HEDIS | A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Accreditation Decisionmaking by businesses about health plan purchasing Decisionmaking by consumers about health plan/provider choice External oversight/Medicaid External oversight/State government program Internal quality improvement NQF: NR
Lipid screening | Schizophrenia | Proportion of patients who have an increased level of blood lipids | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research
Lipid screening | Schizophrenia, bipolar or other psychoses | Percentage of patients aged 40 years or over with schizophrenia, bipolar affective disorder and other psychoses who have a record of total cholesterol: HDL ratio in the preceding 12 months | British Medical Association | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement National reporting Pay-for-performance
Lipid screening | Bipolar Disorder | Percentage of patients diagnosed with bipolar disorder and treated with an atypical antipsychotic agent who received at least one assessment for hyperlipidemia within the initial 16 week period of treatment | CQAIMH STABLE Project National Coordinating Council | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement
Screening for smoking | Bipolar, schizophrenia, bipolar affective disorder or other psychoses | Smoking status of those with coronary heart disease (CHD), stroke or transient ischemic attack (TIA), hypertension, diabetes, chronic obstructive pulmonary disease (COPD), chronic kidney disease (CKD), asthma | NQMC (WITHDRAWN)

Table D-40 Quality measures used in Studies for assessing medical outcomes: Cardiovascular disease

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
CVD risk screening | Mental health disorders | Percentage of patients with diabetes with documented CV risk factor assessment | Kilbourne7 | NA | Framework for measuring quality and promoting accountability across silos: the case of mental disorder and co-occurring conditions
Metabolic screening | Schizophrenia, Bipolar Disorder | Annual assessment of weight/BMI, glycemic control, and lipids | Watkins3 | Veteran's Health Administration | Report on developing medical record-based performance indicators to measure the quality of mental health care
Pulse | Bipolar Disorder | Record pulse | Kilbourne13 used RAND measure | Veteran's Health Administration | Cross-sectional, cumulative data to 2 years prior to assessment
Lipids | Community psychiatric patients prescribed antipsychotics | All patients prescribed continuing antipsychotic medication should have their plasma lipids measured at least once per year | Barnes18 | UK National Health Service secondary care mental health Trusts | Baseline and one year followup audit against evidence based standards for metabolic syndrome
Lipids | Mental health disorders | Percentage of patients initiating a second generation antipsychotic with lipids recorded 12 weeks and 6 months | Kilbourne7 | NA | Framework for measuring quality and promoting accountability across silos: the case of mental disorder and co-occurring conditions
Lipids screening | Schizophrenia, bipolar disorder | Beneficiaries with at least one claim during the study period for a cholesterol test | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder
Smoking cessation advice | Mental health disorders | Percentage of patients who smoke who are advised to quit | Kilbourne7 | NA | Framework for measuring quality and promoting accountability across silos: the case of mental disorder and co-occurring conditions
Smoking cessation | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Staff support to patients with smoking cessation | Killaspy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.
Smoking cessation counseling | Schizophrenia | Patients with schizophrenia who are smokers who receive counseling about smoking in the measurement year | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia

Table D-41 Identified quality measures for medical care in key quality measure databases: Other measures

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Renal and thyroid tests | Schizophrenia, bipolar or other psychoses | Serum creatinine and TSH measurement for those on lithium therapy | British Medical Association | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Internal quality improvement National reporting Pay-for-performance
Cancer screening | Schizophrenia, bipolar or other psychoses | Percentage of women aged 25 years or over and who have not attained the age of 65 with schizophrenia, bipolar affective disorder and other psychoses whose notes record that a cervical screening test has been performed in the preceding 5 years | British Medical Association | A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement National reporting Pay-for-performance

Table D-42 Quality measures used in studies for assessing medical outcomes: Other

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Access to General Practitioner | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Staff support to patients to access general practitioner | Killaspy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.
Annual general health check-ups | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Unit arranges/carries out annual general health check-ups | Killaspy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.
General medical exam | Mental health disorders | Percentage of patients who have a general medical appointment annually | Kilbourne7 | NA | Framework for measuring quality and promoting accountability across silos: the case of mental disorder and co-occurring conditions
General medical monitoring | Schizophrenia | Percentage of patients on antipsychotic medication who receive general medical monitoring at regular assessment intervals (weight, blood sugars, cholesterol) either by the program or by the family physician | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)
General medical monitoring | Schizophrenia | Patients who had an annual assessment of weight/BMI, glycemic control, and lipids | Watkins3 | Veterans Health Administration | Report on developing medical record-based performance indicators to measure the quality of mental health care
Physical health maintenance | Schizophrenia, bipolar disorder | Beneficiaries with at least one claim during the study period for a comprehensive health examination or health behavior counseling | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder
Dietary advice, accessing exercise, sexual health. dental care | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Staff support to patients with dietary advice, accessing exercise, sexual health. dental care | Killaspy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.
Non-psychiatric health care | Schizophrenia, paranoid and other psychoses, organic brain syndrome, or major affective disorder (meeting disability and duration criteria) | Use of non-psychiatric health care services by people with SMI | Charlwood14 | NA | Report on the development and final recommendations for outcome indicators for severe mental illness for the UK from their National Centre for Health Outcomes Development
Physical health (including cancer) | Schizophrenia | Patients with schizophrenia who receive a blood pressure screening, flu shot, mammogram, pap smear, and colorectal cancer screening | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia
Cancer screening | Schizophrenia, bipolar disorder | Beneficiaries with at least one claim for a mammogram, Pap smear, or colonoscopy during the study period | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder
Metabolic conditions | Schizophrenia | Patients with schizophrenia who have a prescription for an antipsychotic medication who receive a screening for blood sugar, lipids, and/or blood pressure during the measurement year | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia
Thyroid tests | Mental health disorders | Percentage of patients on lithium receiving thyroid tests | Kilbourne7 | NA | Framework for measuring quality and promoting accountability across silos: the case of mental disorder and co-occurring conditions
Infectious disease screening | Schizophrenia | Patients with schizophrenia who receive a HIV, HBV, HCV, or other STD screening | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia

Table D-43 Identified quality measures for patient-centered care in key quality measure databases: Employment

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Employment assistance | Schizophrenia | Patients in active treatment who report that they are currently employed and have a prior work history or are actively looking for a job and have 1) participated in a program to help find a job or vocational rehabilitation is prescribed in treatment plan, or 2) report receiving assistance from an employment specialist | CQAIMH Lehman et al, 1998 | Census | NOTE CAN NO LONGER FIND THIS ON CQAIMH WEB SITE

Table D-44 Quality measures used in studies for assessing patient-centered outcomes: Employment

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Supportive employment | Schizophrenia | People with schizophrenia who received or were offered supported employment during the measurement year | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia
Supported employment | Schizophrenia, bipolar disorder | Beneficiaries with at least one supported employment claim during the study period | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder

Table D-45 Identified quality measures for patient-centered care in key quality measure databases: Family involvement

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Contact with family | Schizophrenia | Proportion of patients where relatives accept an offer of contact with the treatment system | The Danish National Schizophrenia Registry | A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research
Contact with family | Schizophrenia, schizoaffective disorder | Patients with a diagnosis for at least three months who had at least one visit with a psychiatrist and no more than 21 days in the hospital and who live either with family members or who have contact with them two or more times per week who had a family member's recent involvement in treatment (e.g. family meeting or phone contact with clinician | CQAIMH, Developer: Young et al, 1998 | AHRQ Level C. Little research evidence, principally based on clinical consensus/opinion | NR

Table D-46 Quality measures used in studies for assessing patient-centered outcomes: Family involvement

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Contact with Family | Psychosis | Clinician contact with a family member and/or supportive other within 72 hours of admission | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Family Involvement | Psychosis | Family involvement in treatment was defined as documentation that included one or more of the following ways of participating in the treatment process:; - Attendance at family therapy sessions; - Attendance at multiple family groups; - Attendance at psycho-educational programs | Williams6 | University Health System Consortium | Retrospective review of inpatient psychiatric records across member academic medical centers; performance measures adapted from consensus projects on important performance measures in mental health and clinical practice guidelines from organizations such as The Joint Commission, the National Quality Forum, and the American Psychiatric Association
Family Involvement | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Number of families involved in patients/ residents care | Killaspy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.
Family Involvement | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Whether staff have meeting with patients and their families | Killaspy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.
Family Involvement | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Whether families invited to patients' care review meetings | Killaspy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.
Family Therapy | Schizophrenia | Family therapy | Busch2 | Medicaid Managed Behavioral Health Carve-Outs | Observational retrospective cohort study of ambulatory care Medicaid enrollees in carve-out and comparison regions
Family Therapy | Schizophrenia | Patients with schizophrenia who have a minimum number of visits for family therapy during the measurement year | Simon5 | NA | Report on developing quality measures for Medicaid Beneficiaries with schizophrenia
Family therapy/pscyho-education | Schizophrenia, bipolar disorder | Beneficiaries with at least one family therapy claim during the study period | Brown10 | NA | Report on evidence-based practice for Medicaid beneficiaries with schizophrenia and bipolar disorder
Family Psycho-education | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Number of families received psychoeducation in past 12 months | Killaspy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.
Family Psycho-education | Schizophrenia | Percentage of family members who receive formal education regarding psychosis (the course of family intervention should be longer than 6 months with more than 10 planned sessions | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)

Table D-47 Identified quality measures for patient-centered care in key quality measure databases: Other measures

Quality of Care Concern | Type of SMI | Full Quality Measure | Developer | Evidence for Measure | Use of Measure
Comprehensive care plan agreement | Schizophrenia, bipolar or other psychoses | Comprehensive Care Plan, agreed between individuals, their family and/or carers as appropriate | British Medical Association | A clinical practice guideline or other peer-reviewed synthesis of the clinical research evidence A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences One or more research studies published in a National Library of Medicine (NLM) indexed, peer-reviewed journal | Internal quality improvement National reporting Pay-for-performance
Social Support | Schizophrenia | Proportion of incident (diagnosed within 12 months of contact) patients for which need for social support has been assessed by a medical social worker | The Danish National Schizophrenia Registry | AHRQ Level B: Fair research evidence and supporting clinical consensus/ opinion A formal consensus procedure, involving experts in relevant clinical, methodological, public health and organizational sciences | Accreditation Collaborative inter-organizational quality improvement Decisionmaking by consumers about health plan/provider choice Decisionmaking by managers about resource allocation External oversight/Regional, county, or city agencies External oversight/State government program Internal quality improvement National reporting Quality of care research

Table D-48 Quality measures used in studies for assessing patient-centered outcomes: Other measures

Quality of Care Concern | Type of SMI | Full Quality Measure | User of Measure for Study | Data Source | Study Details
Autonomy | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Patients decide:: what time they want to wake up/have meals/go to bed/how they spend their money/time off the unit/how many cigarettes and alcohol they consume/whether they stay overnight elsewhere/have a consensual sexual relationship | Killaspy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.
Patient's involvement in choice of medication and dose | Inpatient or community mental health rehabilitation unit patients, mostly with schizophrenia | Degree of patients' influence and involvement in choice of medication and dose | Killaspsy1 | UK National Health Service Mental Health Trusts | Used a web-based toolkit (Quality Indicator for Rehabilitative Care [QuIRC]) reporting on seven domains of care, based on systematic review of effectiveness of components of care, a review of relevant international care standards and Delphi exercises with service users, practitioners, carers and advocates.
Satisfaction with mental health care | Schizophrenia, paranoid and other psychoses, organic brain syndrome, or major affective disorder (meeting disability and duration criteria) | User satisfaction with respect to a specific mental health service, among people with SMI | Charlwood14 | NA | Report on the development and final recommendations for outcome indicators for severe mental illness for the UK from their National Centre for Health Outcomes Development
Quality of Life | Schizophrenia | Percentage of patients receiving an assessment of quality of life at intake (as measured on a structured scale) | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)
Quality of Life | Schizophrenia, paranoid and other psychoses, organic brain syndrome, or major affective disorder (meeting disability and duration criteria) | User-assess health-related quality of life for a service-provider population of people with SMI | Charlwood14 | NA | Report on the development and final recommendations for outcome indicators for severe mental illness for the UK from their National Centre for Health Outcomes Development
Independent Living Skills | Schizophrenia | Percentage of patients receiving an assessment of independent living skills | Addington11 | NA | Development of a core set of performance measures for evaluating schizophrenia treatment services (36 essential measures)
Social Skills Training | Schizophrenia | Patients receiving during the study period any social skills training (and how many visits) | Watkins3 | Veterans Health Administration | Report on developing medical record-based performance indicators to measure the quality of mental health care
Housing status | Schizophrenia, paranoid and other psychoses, organic brain syndrome, or major affective disorder (meeting disability and duration criteria) | Accommodation status of people with SMI | Charlwood14 | NA | Report on the development and final recommendations for outcome indicators for severe mental illness for the UK from their National Centre for Health Outcomes Development

## References

1 Killaspy H, Marston L, Omar RZ, et al. Service quality and clinical outcomes: an example from mental health rehabilitation services in England. Br J Psychiatry. Jan. 2013;202(1):28-34. [pmid: 23060623].
2 Busch AB, Frank RG, Lehman AF. The effect of a managed behavioral health carve-out on quality of care for medicaid patients diagnosed as having schizophrenia. Arch Gen Psychiatry. May. 2004;61(5):442-8. [pmid: 15123488].
3 Watkins K, Horvitz-Lennon M, Caldarone LB, et al. Developing medical record-based performance indicators to measure the quality of mental healthcare. J Healthc Qual. Jan-Feb. 2011;33(1):49-66. quiz -7. [pmid: 21199073].
4 Lind A. Measuring Quality for Complex Medicaid Beneficiaries in New York. New York. Medicaid Institute™ at United Hospital Fund. 2011.
5 Simon S, Croghan T, Saunders RC, et al. Developing Quality Measures for Medicaid Beneficiaries with Schizophrenia: Final Report. Washington, DC. U.S. Department of Health and Human Services. 2012. http://aspe.hhs.gov/daltcp/reports/2012/schqm.shtml.
6 Williams TL, Cerese J, Cuny J, et al. Outcomes of an initial set of standardized performance measures for inpatient mental health. Jt Comm J Qual Patient Saf. Jul. 2008;34(7):399-406. [pmid: 18677871].
7 Kilbourne AM, Fullerton C, Dausey D, et al. A framework for measuring quality and promoting accountability across silos: the case of mental disorders and co-occurring conditions. Qual Saf Health Care. Apr. 2010;19(2):113-6. [pmid: 20142404].
8 Owen RR, Thrush CR, Hudson TJ, et al. Using an explicit guideline-based criterion and implicit review to assess antipsychotic dosing performance for schizophrenia. Int J Qual Health Care. Jun. 2002;14(3):199-206. [pmid: 12108530].
9 Owen RR, Thrush CR, Kirchner JE, et al. Performance measurement for schizophrenia: adherence to guidelines for antipsychotic dose. Int J Qual Health Care. Dec. 2000;12(6):475-82. [pmid: 11202601].
10 Brown JD, Barrett A, Ireys H, et al. Evidence-Based Practices for Medicaid Beneficiaries with Schizophrenia and Bipolar Disorder. Washington, DC. U.S. Department of Health and Human Services. 2012. http://aspe.hhs.gov/daltcp/reports/2012/ebpsbd.pdf.
11 Addington DE, McKenzie E, Wang J, et al. Development of a core set of performance measures for evaluating schizophrenia treatment services. Psychiatr Serv. Jun. 2012;63(6):584-91. [pmid: 22476226].
12 Duffy FF, Narrow W, West JC, et al. Quality of care measures for the treatment of bipolar disorder. Psychiatr Q. Fall. 2005;76(3):213-30. [pmid: 16080418].
13 Kilbourne AM, Farmer Teh C, Welsh D, et al. Implementing composite quality metrics for bipolar disorder: towards a more comprehensive approach to quality measurement. Gen Hosp Psychiatry. Nov-Dec. 2010;32(6):636-43. [pmid: 21112457].
14 Charlwood P. Severe mental illness Report of a working group to the Department of Health. London. National Centre for Health Outcomes Development (United Kingdom). 1999. http://hdl.handle.net/10068/547224.
15 Druss BG, Miller CL, Pincus HA, et al. The volume-quality relationship of mental health care: does practice make perfect?. Am J Psychiatry. Dec. 2004;161(12):2282-6. [pmid: 15569901].
16 Plever S, McCarthy I, Emmerson B, et al. Clinical Practice Improvement Payments: incentives for delivery of quality care. Australas Psychiatry. Oct. 2012;20(5):407-12. [pmid: 23014128].
17 Adams P, Nielson H. Evidence based practice: decreasing psychiatric revisits to the emergency department. Issues Ment Health Nurs. Aug. 2012;33(8):536-43. [pmid: 22849781].
18 Barnes TR, Paton C, Hancock E, et al. Screening for the metabolic syndrome in community psychiatric patients prescribed antipsychotics: a quality improvement programme. Acta Psychiatr Scand. Jul. 2008;118(1):26-33. [pmid: 18582345].