# Full Text Excludes

Exclusion Code Key
- XL=Ineligible language (not in English)
- X1=Ineligible publication type, ineligible study design, or not original research
- X2=Ineligible population
- X3=Ineligible or no intervention
- X4=Ineligible or no comparison group
- X5=Ineligible outcome

1 Perlman CM, Hirdes JP, Barbaree H, et al. Development of mental health quality indicators (MHQIs) for inpatient psychiatry based on the interRAI mental health assessment. BMC Health Serv Res. 2013;13:15. Exclusion Code: X3. [pmid: 23305286].
2 Killaspy H, Marston L, Omar RZ, et al. Service quality and clinical outcomes: an example from mental health rehabilitation services in England. Br J Psychiatry. Jan. 2013;202(1):28-34. Exclusion Code: X3. [pmid: 23060623].
3 Hunt Glenn E, Siegfried N, Morley K, et al. Psychosocial interventions for people with both severe mental illness and substance misuse. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2013. Exclusion Code: X3.
4 Barley E, Borschmann R, Walters P, et al. Interventions to encourage uptake of cancer screening for people with severe mental illness. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2013. Exclusion Code: X3.
5 Reilly S, Planner C, Gask L, et al. Collaborative care approaches for people with severe mental illness. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2013. Exclusion Code: X3.
6 Gierisch JM, Nieuwsma JA, Bradford DW, et al. Interventions to improve cardiovascular risk factors in people with serious mental illness. Report No: 13-EHC063-EF. Agency for Healthcare Research and Quality. 2013. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12013022147/frame.html. Exclusion Code: X3.
7 Chow CM, Wieman D, Cichocki B, et al. Mission impossible: treating serious mental illness and substance use co-occurring disorder with integrated treatment: a meta-analysis. Mental Health and Substance Use. 2013:150-68. Exclusion Code: X3.
8 Deuschle M, Paul F, Brosz M, et al. Assessment of cardiovascular disease risk in patients with schizophrenia spectrum disorders in German psychiatric hospitals: results of the pharmacoepidemiologic CATS study. Soc Psychiatry Psychiatr Epidemiol. 2013;48(8):1283-8. Exclusion Code: X3. [pmid: 23515714].
9 Bella M, Somers SA, Llanos K. Providing Behavioral Health Services to Medicaid Managed Care Enrollees. Options for Improving the Organization and Delivery of Services. New York. Medicaid Institute™ at United Hospital Fund. 2009. Exclusion Code: X1.
10 Lind A. Measuring Quality for Complex Medicaid Beneficiaries in New York. New York. Medicaid Institute™ at United Hospital Fund. 2011. Exclusion Code: X1.
11 Brown JD, Barrett A, Ireys H, et al. Evidence-Based Practices for Medicaid Beneficiaries with Schizophrenia and Bipolar Disorder. Washington, DC. U.S. Department of Health and Human Services. 2012. http://aspe.hhs.gov/daltcp/reports/2012/ebpsbd.pdf. Exclusion Code: X1.
12 Simon S Croghan T Saunders RC Developing Quality Measures for Medicaid Beneficiaries with Schizophrenia: Final Report Washington, DC U.S. Department of Health and Human Services 2012 http://aspe.hhs.gov/daltcp/reports/2012/schqm.shtml. Exclusion Code: X1
13 Alakeson V. The Contribution of Self-Direction to Improving the Quality of Mental Health Services. Washington, DC. U.S. Department of Health and Human Services. 2007. Exclusion Code: X3.
14 Schwalbe L. Behavioral Health Providers: Expenditures, Methods and Sources of Payment, Electronic Health Record Incentive Payments for Certain Behavioral Health Providers Policy Descriptions. Washington, DC. U.S. Department of Health and Human Services. 2010. http://aspe.hhs.gov/daltcp/reports/2010/behhp.htm. Exclusion Code: X1.
15 Lewin Group. ASPE Technical Expert Panel on Earlier Intervention for Serious Mental Illness: Summary of Major Themes. Washington, DC. U.S. Department of Health and Human Services. 2009. http://aspe.hhs.gov/daltcp/reports/2009/TEPonEI.pdf. Exclusion Code: X3.
16 Charlwood P. Severe mental illness Report of a working group to the Department of Health. National Centre for Health Outcomes Development (United Kingdom). London. 1999. http://hdl.handle.net/10068/547224. Exclusion Code: X1.
17 Plever S, McCarthy I, Emmerson B, et al. Clinical Practice Improvement Payments: incentives for delivery of quality care. Australas Psychiatry. Oct. 2012;20(5):407-12. Exclusion Code: X4. [pmid: 23014128].
18 Adams P, Nielson H. Evidence based practice: decreasing psychiatric revisits to the emergency department. Issues Ment Health Nurs. Aug. 2012;33(8):536-43. Exclusion Code: X3. [pmid: 22849781].
19 IT vendor survey. Behav Healthc. Sep. 2011;31(6):12-7. Exclusion Code: X1. [pmid: 22026107].
20 Grantham D. Maximize your EHR incentives. Everything you wanted to know about HITECH EHR incentives, but were afraid to ask. Behav Healthc. Jul-Aug. 2010;30(7):10-5. Exclusion Code: X1. [pmid: 22195308].
21 Kilbourne AM, Greenwald DE, Hermann RC, et al. Financial incentives and accountability for integrated medical care in Department of Veterans Affairs mental health programs. Psychiatr Serv. Jan. 2010;61(1):38-44. Exclusion Code: X5. [pmid: 20044416].
22 Bellows NM, Halpin HA. Impact of Medicaid reimbursement on mental health quality indicators. Health Serv Res. Apr. 2008;43(2):582-97. Exclusion Code: X2. [pmid: 18370968].
23 Macias C, Rodican CF, Hargreaves WA, et al. Supported employment outcomes of a randomized controlled trial of ACT and clubhouse models. Psychiatr Serv. Oct. 2006;57(10):1406-15. Exclusion Code: X3. [pmid: 17035557].
24 Hodgkin D, Horgan CM, Garnick DW, et al. Quality standards and incentives in managed care organizations' specialty contracts for behavioral health. J Ment Health Policy Econ. Jun. 2002;5(2):61-9. Exclusion Code: X2. [pmid: 12529562].
25 Parameswaran S, Spaeth-Rublee B, Huynh PT, et al. Comparison of national mental health quality assessment programs across the globe. Psychiatr Serv. Oct. 2012;63(10):983-8. Exclusion Code: X1. [pmid: 22855298].
26 Addington DE, McKenzie E, Wang J. Validity of hospital admission as an outcome measure of services for first-episode psychosis. Psychiatr Serv. Mar. 2012;63(3):280-2. Exclusion Code: X3. [pmid: 22267251].
27 Pfeiffer PN, Ganoczy D, Zivin K, et al. Outpatient follow-up after psychiatric hospitalization for depression and later readmission and treatment adequacy. Psychiatr Serv. Dec. 2012;63(12):1239-42. Exclusion Code: X2. [pmid: 23203359].
28 Teague GB, Mueser KT, Rapp CA. Advances in fidelity measurement for mental health services research: four measures. Psychiatr Serv. Aug. 2012;63(8):765-71. Exclusion Code: X1. [pmid: 22854723].
29 Cohen A. The QOF, NICE, and depression. Br J Gen Pract. Sep. 2011;61(590):549. Exclusion Code: X1. [pmid: 22152732].
30 Kilbourne AM, Fullerton C, Dausey D, et al. A framework for measuring quality and promoting accountability across silos: the case of mental disorders and co-occurring conditions. Qual Saf Health Care. Apr. 2010;19(2):113-6. Exclusion Code: X3. [pmid: 20142404].
31 Williams TL, Cerese J, Cuny J, et al. Outcomes of an initial set of standardized performance measures for inpatient mental health. Jt Comm J Qual Patient Saf. Jul. 2008;34(7):399-406. Exclusion Code: X1. [pmid: 18677871].
32 Unutzer J, Chan YF, Hafer E, et al. Quality improvement with pay-for-performance incentives in integrated behavioral health care. Am J Public Health. Jun. 2012;102(6):e41-5. Exclusion Code: X2. [pmid: 22515849].
33 Kilbourne AM, Rofey DL, McCarthy JF, et al. Nutrition and exercise behavior among patients with bipolar disorder. Bipolar Disord. Aug. 2007;9(5):443-52. Exclusion Code: X3. [pmid: 17680914].
34 Kilbourne AM, Lai Z, Bowersox N, et al. Does colocated care improve access to cardiometabolic screening for patients with serious mental illness?. Gen Hosp Psychiatry. Nov-Dec. 2011;33(6):634-6. Exclusion Code: X3. [pmid: 21872334].
35 Kilbourne AM, Pirraglia PA, Lai Z, et al. Quality of general medical care among patients with serious mental illness: does colocation of services matter?. Psychiatr Serv. Aug. 2011;62(8):922-8. Exclusion Code: X4. [pmid: 21807832].
36 Pirraglia PA, Kilbourne AM, Lai Z, et al. Colocated general medical care and preventable hospital admissions for veterans with serious mental illness. Psychiatr Serv. May. 2011;62(5):554-7. Exclusion Code: X4. [pmid: 21532086].
37 Kilbourne AM, Post EP, Bauer MS, et al. Therapeutic drug and cardiovascular disease risk monitoring in patients with bipolar disorder. J Affect Disord. Sep. 2007;102(1-3):145-51. Exclusion Code: X3. [pmid: 17276514].
38 Kilbourne AM, Welsh D, McCarthy JF, et al. Quality of care for cardiovascular disease-related conditions in patients with and without mental disorders. J Gen Intern Med. Oct. 2008;23(10):1628-33. Exclusion Code: X3. [pmid: 18626722].
39 Brissos S, Molodynski A, Dias VV, et al. The importance of measuring psychosocial functioning in schizophrenia. Ann Gen Psychiatry. 2011;10:18. Exclusion Code: X3. [pmid: 21702932].
40 Sherring J, Robson E, Morris A, et al. A working reality: evaluating enhanced intersectoral links in supported employment for people with psychiatric disabilities. Aust Occup Ther J. Aug. 2010;57(4):261-7. Exclusion Code: X3. [pmid: 20854601].
41 Salyers MP, McGuire AB, Rollins AL, et al. Integrating assertive community treatment and illness management and recovery for consumers with severe mental illness. Community Ment Health J. Aug. 2010;46(4):319-29. Exclusion Code: X3. [pmid: 20077006].
42 Bassani DG, Dewa CS, Krupa T, et al. Factor structure of the Multnomah Community Ability Scale--longitudinal analysis. Psychiatry Res. May. 15. 2009;167(1-2):178-89. Exclusion Code: X3. [pmid: 19361868].
43 Adair CE, McDougall GM, Mitton CR, et al. Continuity of care and health outcomes among persons with severe mental illness. Psychiatr Serv. Sep. 2005;56(9):1061-9. Exclusion Code: X4. [pmid: 16148318].
44 Burger GK, Yonker RD, Calsyn RJ, et al. Generalizability of brief psychiatric rating scale prototypical profiles and their use in evaluating treatment outcomes. Int J Methods Psychiatr Res. 2005;14(1):56-64. Exclusion Code: X1. [pmid: 16097400].
45 Brown C, Moore WP, Hemman D, et al. Influence of instrumental activities of daily living assessment method on judgments of independence. Am J Occup Ther. Mar. 1996;50(3):202-6. Exclusion Code: X4. [pmid: 8822243].
46 Kilbourne AM, Farmer Teh C, Welsh D, et al. Implementing composite quality metrics for bipolar disorder: towards a more comprehensive approach to quality measurement. Gen Hosp Psychiatry. Nov-Dec. 2010;32(6):636-43. Exclusion Code: X3. [pmid: 21112457].
47 Barnes TR, Paton C, Hancock E, et al. Screening for the metabolic syndrome in community psychiatric patients prescribed antipsychotics: a quality improvement programme. Acta Psychiatr Scand. Jul. 2008;118(1):26-33. Exclusion Code: X2. [pmid: 18582345].
48 Whyte S, Penny C, Phelan M, et al. Quality of diabetes care in patients with schizophrenia and bipolar disorder: cross-sectional study. Diabet Med. Dec. 2007;24(12):1442-8. Exclusion Code: X3. [pmid: 18042084].
49 Busch AB, Huskamp HA, Landrum MB. Quality of care in a Medicaid population with bipolar I disorder. Psychiatr Serv. Jun. 2007;58(6):848-54. Exclusion Code: X4. [pmid: 17535947].
50 Goldberg RW, Kreyenbuhl JA, Medoff DR, et al. Quality of diabetes care among adults with serious mental illness. Psychiatr Serv. Apr. 2007;58(4):536-43. Exclusion Code: X4. [pmid: 17412857].
51 Chong SA, Vaingankar JA, Chan YH, et al. Assessing the quality of care for patients with first-episode psychosis. Singapore Med J. Oct. 2006;47(10):882-5. Exclusion Code: X3. [pmid: 16990964].
52 Gorrell J, Cornish A, Tennant C, et al. Changes in early psychosis service provision: a file audit. Aust N Z J Psychiatry. Sep. 2004;38(9):687-93. Exclusion Code: X2. [pmid: 15324332].
53 Weinmann S, Roick C, Martin L, et al. Development of a set of schizophrenia quality indicators for integrated care. Epidemiol Psichiatr Soc. Jan-Mar. 2010;19(1):52-62. Exclusion Code: XL. [pmid: 20486424].
54 Kilbourne AM, Keyser D, Pincus HA. Challenges and opportunities in measuring the quality of mental health care. Can J Psychiatry. Sep. 2010;55(9):549-57. Exclusion Code: X1. [pmid: 20840802].
55 Tosh G, Clifton Andrew V, Xia J, et al. General physical health advice for people with serious mental illness. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2014. Exclusion Code: X4.
56 Tosh G, Clifton Andrew V, Xia J, et al. Physical health care monitoring for people with serious mental illness. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2014. Exclusion Code: X4.
57 Druss BG, Zhao L, Cummings JR, et al. Mental comorbidity and quality of diabetes care under Medicaid: a 50-state analysis. Med Care. May. 2012;50(5):428-33. Exclusion Code: X4. [pmid: 22228248].
58 Moeller KE, Rigler SK, Mayorga A, et al. Quality of monitoring for metabolic effects associated with second generation antipsychotics in patients with schizophrenia on public insurance. Schizophr Res. Mar. 2011;126(1-3):117-23. Exclusion Code: X3. [pmid: 21168994].
59 Cullen BA, McGinty EE, Zhang Y, et al. Guideline-concordant antipsychotic use and mortality in schizophrenia. Schizophr Bull. Sep. 2013;39(5):1159-68. Exclusion Code: X3. [pmid: 23112292].
60 McGinty EE, Blasco-Colmenares E, Zhang Y, et al. Post-myocardial-infarction quality of care among disabled Medicaid beneficiaries with and without serious mental illness. Gen Hosp Psychiatry. Sep-Oct. 2012;34(5):493-9. Exclusion Code: X4. [pmid: 22763001].
61 Valenstein M, Copeland LA, Blow FC, et al. Pharmacy data identify poorly adherent patients with schizophrenia at increased risk for admission. Med Care. Aug. 2002;40(8):630-9. Exclusion Code: X3. [pmid: 12187177].
62 Valenstein M, Ganoczy D, McCarthy JF, et al. Antipsychotic adherence over time among patients receiving treatment for schizophrenia: a retrospective review. J Clin Psychiatry. Oct. 2006;67(10):1542-50. Exclusion Code: X3. [pmid: 17107245].
63 Lehman AF, Steinwachs DM. Patterns of usual care for schizophrenia: initial results from the Schizophrenia Patient Outcomes Research Team (PORT) Client Survey. Schizophr Bull. 1998;24(1):11-20. discussion -32. Exclusion Code: X1. [pmid: 9502543].
64 Busch AB, Frank RG, Sachs G. Bipolar-I depression outpatient treatment quality and costs in usual care practice. Psychopharmacol Bull. 2008;41(2):24-39. Exclusion Code: X3. [pmid: 18668015].
65 Unutzer J, Simon G, Pabiniak C, et al. The use of administrative data to assess quality of care for bipolar disorder in a large staff model HMO. Gen Hosp Psychiatry. Jan-Feb. 2000;22(1):1-10. Exclusion Code: X3. [pmid: 10715498].
66 Dixon L, Perkins D, Calmes C. Guideline Watch (September 2009): Practice Guideline for the Treatment of Patients with Schizophrenia. psychiatryonline.org. American Psychiatric Publishing, Inc. 2010. Exclusion Code: X3.
67 Hirschfeld RMA. Guideline Watch: Practice Guideline for the Treatment of Patients with Bipolar Disorder, 2nd Edition. psychiatryonline.org. American Psychiatric Publishing, Inc. 2005. Exclusion Code: X3.