# Search Strategy and Yields

Pub Med Search Terms (November 2013)

Search # | Query | Items Found
#1 | Search “Quality Indicators, Health Care”[Mesh] | 12097
#2 | Search “Mood Disorders”[Mesh] OR “Schizophrenia and Disorders with Psychotic Features”[Mesh] OR ((severe OR serious OR persistent) mental illness[Text Word]) | 213560
#4 | Search (#1 AND #2) Filters: Humans | 99
#5 | Search (#1 AND #2) Filters: Humans; Adult: 19+ years | 61
#6 | Search (#1 AND #2) Filters: Humans; English; Adult: 19+ years | 56
#7 | Search ((“Mental Health Services”[Mesh] OR “Community Mental Health Services”[Mesh])) Filters: Humans; English; Adult: 19+ years | 23249
#9 | Search (#1 AND #7) Filters: Humans; English; Adult: 19+ years | 89
#11 | Search (#6 OR #9) Filters: Humans; English; Adult: 19+ years | 127
#13 | Search “Mental Health Services/standards”[MAJR] Filters: Humans; English; Adult: 19+ years | 932
#15 | Search (#1 AND #13) Filters: Humans; English; Adult: 19+ years | 41
#17 | Search (#11 OR #15) Filters: Humans; English; Adult: 19+ years | 127

Additional Pub Med Searches (December 2013)

Search # | Query | Items Found
#1 | Search medicaid reform | 2375
#2 | Search medicaid reform mental health measures | 7
#7 | Search “Quality Indicators, Health Care”[Mesh] | 11876
#10 | Search “Health Care Reform”[Mesh] | 27355
#11 | Search (#7 AND #10) | 213
#13 | Search “Mental Health”[Mesh] OR “Mental Health Services”[Mesh] | 90197
#14 | Search (#11 AND #13) | 7
#15 | Search pay for (performance OR reporting) | 4860
#16 | Search (#13 AND #15) | 74
#17 | Search (#13 AND #15) Filters: Humans | 67
#18 | Search (#13 AND #15) Filters: Humans; English | 66
#19 | Search (#18 AND #17) Filters: Humans; English | 66

Search # | Query | Items Found
#3 | Search “Reimbursement, Incentive”[MAJR] | 1795
#4 | Search “Mental Disorders/therapy”[MeSH Terms] | 327010
#5 | Search (#3 AND #4) | 30
#6 | Search (#3 AND #4) Filters: Humans | 30
#7 | Search (#3 AND #4) Filters: Humans; English | 30

Medicaid Reform New = 0

Pay for Performance/Reporting New = 74

Search # | Query | Items Found
#5 | Search (“Quality Assurance, Health Care”[Majr]) AND “Quality Indicators, Health Care”[Majr] | 1451
#6 | Search (“Quality Assurance, Health Care”[Majr]) AND “Quality Indicators, Health Care”[Majr] Filters: Humans | 1265
#7 | Search (“Quality Assurance, Health Care”[Majr]) AND “Quality Indicators, Health Care”[Majr] Filters: Humans; English | 1132
#8 | Search (“Quality Assurance, Health Care”[Majr]) AND “Quality Indicators, Health Care”[Majr] Filters: Humans; English; Adult: 19+ years | 242
#12 | Search “Mental Disorders”[Mesh] Filters: Humans; English | 707192
#14 | Search “Mental Health Services”[Mesh] Filters: Humans; English | 58800
#15 | Search (#12 OR #14) Filters: Humans; English | 739957
#16 | Search (#7 AND #15) Filters: Humans; English | 47

Additions based on suggestions = 47 = 25 new

Cochrane = 8 = new

PsycInfo = 11 = new

OpenGrey = 23

ClinicalTrials.gov = 4

Academic Search Complete = 5 = new

HAPI = 0

ERIC = 4

NIH RePORTer = 14

National Guidelines Clearinghouse (NGC) = 0 new

National Quality Measures Clearinghouse (NQMC) = 0 new

The Joint Commission) = 0 new

Hand entered = 9

Total Unduplicated Database = 195

Search # | Query | Items Found
#2 | Search puschner b | 131
#3 | Search puschner b AND CEDAR | 2
#6 | Search CEDAR study group[Corporate Author] | 1
#7 | Search ISRCTN75841675 | 3
#9 | Search 23379280[uid] | 1

Update Pub Med Search (August 2014)

Search # | Query | Items Found
#1 | Search “Quality Indicators, Health Care”[Mesh] | 12882
#2 | Search ((severe OR serious OR persistent) mental illness[Text Word]) | 5356
#3 | Search (#1 AND #2) | 16
#4 | Search (#1 AND #2) Filters: Publication date from 2013/06/01; Humans; English; Adult: 19+ years | 0
#7 | Search “Mood Disorders”[Mesh] OR “Schizophrenia and Disorders with Psychotic Features”[Mesh]OR Depression[Mesh] OR ((“Depressive Disorder, Major”[Mesh]) OR “Anxiety Disorders”[Mesh]) OR “Eating Disorders”[Mesh] OR “Personality Disorders”[Mesh] OR ((severe OR serious OR persistent) mental illness[Text Word]) | 370754
#8 | Search (#1 AND #7) Filters: Publication date from 2013/06/01 | 8
#9 | Search (#1 AND #7) | 161
#11 | Search (“Mental Health Services”[Mesh] OR “Community Mental Health Services”[Mesh]) | 73810
#12 | Search (#1 AND #11) Filters: Publication date from 2013/06/01 | 5
#13 | Search (#1 AND #11) | 270
#15 | Search (“Mental Health Services/standards”[MAJR]) | 3690
#16 | Search (#1 AND #15) Filters: Publication date from 2013/06/01 | 1
#17 | Search (#1 AND #15) | 139
#22 | Search (#16 OR #12 OR #8) Filters: Publication date from 2013/06/01; Humans; English; Adult: 19+ years | 11

Search # | Query | Items Found
#2 | Search medicaid reform | 2537
#3 | Search medicaid reform mental health measures | 7
#4 | Search “Quality Indicators, Health Care”[Mesh] | 12882
#5 | Search “Health Care Reform”[Mesh] | 28374
#6 | Search (#4 AND #5) | 226
#7 | Search “Mental Health”[Mesh] OR “Mental Health Services”[Mesh] | 93486
#8 | Search (#6 AND #7) | 5
#9 | Search pay for (performance OR reporting) | 2751
#10 | Search (#7 AND #9) | 61
#11 | Search (#3 OR #8 OR #10) | 44
#12 | Search (#3 OR #8 OR #10) Filters: English | 43
#13 | Search (#3 OR #8 OR #10) Filters: Humans; English | 42
#14 | Search (#3 OR #8 OR #10) Filters: Publication date from 2013/06/01; Humans; English | 5

Search # | Query | Items Found
#1 | Search “Reimbursement, Incentive”[MAJR] Filters: Publication date from 2013/06/01; Humans; English | 36
#2 | Search “Reimbursement, Incentive”[MAJR] | 1916
#3 | Search “Mental Disorders/therapy”[MeSH Terms] Filters: Publication date from 2013/06/01; Humans; English | 1579
#4 | Search “Mental Disorders/therapy”[MeSH Terms] | 338119
#5 | Search (#1 AND #3) Filters: Publication date from 2013/06/01; Humans; English | 0

Search # | Query | Items Found
#1 | Search ((“Quality Assurance, Health Care”[Majr]) AND “Quality Indicators, Health Care”[Majr]) Filters: Publication date from 2013/06/01; Humans; English | 27
#2 | Search ((“Quality Assurance, Health Care”[Majr]) AND “Quality Indicators, Health Care”[Majr]) | 1541
#3 | Search ((“Quality Assurance, Health Care”[Majr]) AND “Quality Indicators, Health Care”[Majr]) Filters: Publication date from 2013/06/01; Humans; English; Adult: 19+ years | 5
#4 | Search “Mental Disorders”[Mesh] Filters: Publication date from 2013/06/01; Humans; English | 4589
#6 | Search “Mental Health Services”[Mesh] Filters: Publication date from 2013/06/01; Humans; English | 343
#9 | Search (#4 OR #6) | 4810
#10 | Search (#2 AND #9) Filters: Publication date from 2013/06/01; Humans; English | 0

Search # | Query | Items Found
#1 | Search “Psychometrics”[Mesh] Filters: Publication date from 2013/06/01; Humans; English | 332
#3 | Search ((severe OR serious OR persistent) mental illness[Text Word])Filters: Publication date from 2013/06/01; Humans; English | 1619
#4 | Search (#1 AND #3) Filters: Publication date from 2013/06/01; Humans; English | 5

Search # | Query | Items Found
#3 | Search CEDAR study group[Corporate Author] | 2
#4 | Search ISRCTN75841675 | 5
#5 | Search (#3 OR #4) | 5
#6 | Search (#3 OR #4) Filters: Publication date from 2013/06/01 | 2

PubMed new = 22

Cochrane = 4

PsycInfo = 6 = 5 new

OpenGrey = 0

ClinicalTrials.gov = 1

Academic Search Complete = 3 = 1 new

HAPI = 0

ERIC = 0

NIH RePORTer = 6 = 4 new

Total New Database = 37