# Key Informant Interview and Literature Search Methodology

## Key Informant Interview Methodology

We adhered to the Office of Management and Budget (OMB) requirements and limited standardized questions (the list of Guiding Questions [GQs]) to no more than 9 nongovernment-associated individuals. As a result, we did not need to obtain OMB clearance for the interviews.

After review and approval of the completed Disclosure of Interest forms for the proposed Key Informants (KIs) by the Agency for Healthcare and Quality (AHRQ), over a 6-week period, we conducted interviews with 11 selected KIs, 2 of whom were government-associated individuals and did not count toward the OMB limit of 9 individuals who could be interviewed without clearance. The interviews were a combination of individual KIs and groups of KIs based on availability and concordance of perspectives. A co-investigator from the Evidence-based Practice Center (EPC) team led each of the KI interviews, and the Task Order Officer (TOO) was in attendance for all of the interviews along with other EPC team members. The recorded KI interviews ranged in duration from 1.0 hours to 1.5 hours. Following each interview, we summarized the interviews in writing by incorporating summary notes prepared by team members; interview recordings; and, for some, a professional transcription of the interview. We then submitted notes to the TOO for documentation. Using NVivo^®^ qualitative software (v9.0), we auto-coded the KIs' responses by relevant GQs and subquestions and generated summary reports by subquestion for analysis by the authors. Authors evaluated summary reports, corrected or added codes by referring to the original summary notes, and identified key themes from multiple perspectives. In addition, authors also identified unique perspectives from KIs.

## Literature Search Methodology

Sources for the gray literature include the following:

- HAPI: Health and Psychosocial Instruments provide bibliographic access and descriptions of tests, manuals, rating scales, and other instruments used to assess health and behavior. Assists researchers and others in locating instruments used in the health fields, psychosocial sciences, occupational sciences, library and information science, and education.
- OpenSIGLE: Operated by GreyNet, the OpenSIGLE Repository preserves and makes openly accessible research results originating in the International Conference Series on Grey Literature. GreyNet together with the Institute for Scientific and Technical Information-National Center for Scientific Research designed the format for a metadata record, which encompasses standardized PDF attachments for full-text conference preprints, PowerPoint presentations, abstracts and biographical notes. All 11 volumes (1993–2009) of the GL Conference Proceedings are available in the OpenSIGLE Repository.
- ClinicalTrials.gov: ClinicalTrials.gov offers up-to-date information for locating federally and privately supported clinical trials for a wide range of diseases and conditions. The site currently contains approximately 12,400 clinical studies sponsored by the National Institutes of Health, other Federal agencies, and private industry. Studies listed in the database are conducted in all 50 States and in more than 100 countries.
- Academic Search Complete: This source provides information from a wide range of academic areas, including business, social sciences, humanities, general academic, general science, education and multicultural topics. This multidisciplinary database features full-text for more than 4,000 journals with many dating back to 1975, abstracts and indexing for more than 8,200 scholarly journals, and coverage of selected newspapers and other news sources.
- NIH RePORTER: The information found in RePORTER is drawn from several extant databases (eRA databases, Medline®, PubMed Central, the NIH Intramural Database, and iEdison), using newly formed linkages among these disparate data sources.
- ERIC: Produced by the Educational Resource Information Center, this source provides indexing and abstracting for journal and report literature (1966 to the present) in education and related disciplines. Also includes curricular materials such as courses of study, books, conferences papers and theses.