# Summary and Implications

Currently, there is a relatively small amount of published reports pertaining to imaging evaluation of treatment response among metastatic breast cancer patients. Most reports were from small, single-institution, nonrandomized observational studies. Our review of the literature, along with Key Informant opinion, suggested that FDG-PET/CT is the imaging modality of choice for assessing tumor response among metastatic breast cancer patients over conventional imaging (including CT, MRI, and bone scintigraphy). This preference is due to FDG-PET/CT theoretically providing information regarding functional tumor response to chemotherapy or hormone therapy by measuring changes in tumor metabolism, whereas conventional imaging can only demonstrate gross morphologic changes of tumors in a delayed fashion. Moreover, some early evidence suggested that the metabolic response assessed by FDG-PET/CT after initial cycles of chemotherapy may be predictive of response to treatment among metastatic breast cancer patients, but more rigorous research is needed before definitive conclusions can be reached.

Nevertheless, conventional imaging by CT, MRI, and bone scintigraphy are the most common comparators in studies evaluating the ability of FDG-PET/CT to determine tumor response and are also considered appropriate care. The choice of imaging modality for conventional imaging is dependent upon the location of known metastases (e.g., MRI is best for evaluating brain metastases, CT is best for evaluating lung metastases, and bone scintigraphy is best for evaluating skeletal metastases). The few studies evaluating specific sites of breast cancer metastases pertained to the bone, demonstrating improved response detection for PET/CT over conventional imaging. However, larger-scale studies are required to truly demonstrate the comparative effectiveness of PET/CT and conventional imaging for specific sites of breast cancer metastases with regard to outcomes such as progression-free survival, and decreased chemotoxicity, with earlier stoppage of ineffective therapies. In particular, we did not find reports in the published literature on changes in treatment decisions following the various types of imaging, which could provide information on whether changes identified by different modalities were more likely to alter treatment regimens and, in turn, affect survival times. Changes in treatment regimen may be a particularly important outcome to study in women with bone dominant metastatic breast cancer, since healing bones may appear as “flares” on bone scans, and treatment that is, in fact, working, may inappropriately be changed. Bone dominant metastatic patients have largely been excluded from published studies on treatment response by imaging, and represent an area in need of further research.

The major limitation noted by both the available studies and Key Informants regarding PET/CT for evaluating treatment response is the mechanism of FDG, the only FDA-approved radiotracer for breast cancer imaging. FDG is an indicator of glucose metabolism within cells rather than a direct measure of tumor proliferation. Small pilot studies have reported on the efficacy of several novel tracers that may be able to measure tumor behavior at the molecular level more directly. With a majority of breast cancer patients having estrogen-receptor positive disease, FES may be able to predict the response of metastatic breast cancers to hormonal therapy (e.g., tamoxifen) and to help guide treatment decisions. FLT is another novel radiotracer that was developed as a marker for cellular proliferation, and it may be less susceptible to early inflammatory response to therapy compared with FDG. Future research on novel radiotracers may help clarify heterogeneous breast cancer tumor biology and allow discovery of treatments that might be successful in improving outcomes.

Another major limitation of the published literature on imaging used for treatment evaluation of metastatic breast cancer was the lack of description of potential sources of noise and bias in the imaging machines and protocols that were described in the studies. Although many of the reviewed published literature studies examined small populations of metastatic breast cancer patients who received their scans on the same machines with the same imaging protocols, only one study18 published data on the reproducibility of scans at different time points. This is especially an issue for women who receive imaging from different devices, or even imaging facilities, over the course of their cancer treatment. Future studies should provide information on the quantitative characteristics of the imaging devices so that comparative effectiveness results can be obtained.

Beyond using conventional imaging as a comparator to PET/CT, a few pilot studies have also attempted to evaluate the efficacy of measuring CTCs as biomarkers for therapeutic monitoring in metastatic breast cancer patients. Early data are inconclusive as to whether measuring CTCs has added value beyond functional PET/CT imaging for assessing immediate response to chemotherapy. With regard to new imaging modalities, PET/MRI may hold promise in the evaluation of metastases to the brain; however, it is not currently in wide use. Both biomarkers like CTCs and novel imaging modalities like PET/MRI warrant further development and evaluation in select subpopulations of metastatic breast cancer patients.

The most glaring knowledge gap with regard to imaging evaluation for treatment response in metastatic breast cancer was the evaluation of patient-centered outcomes. None of the published studies examined how the imaging experience or imaging findings affected patient satisfaction, patient anxiety levels, or other outcome measures that may be of central importance to metastatic breast cancer patients beyond survival benefit. Based on Key Informant input, metastatic breast cancer patients are currently under-informed regarding the role of medical imaging in determining treatment response and its ability to guide treatment decisions. Patients are also under-informed with regard to the alternatives to monitoring response by imaging. Future research efforts should address patient-centered outcome measures and shared decision-making associated with imaging evaluation for treatment response.

Finally, no studies addressed the issue of resource use and costs associated with imaging evaluation for treatment response for metastatic breast cancer. However, if PET/CT can correctly predict response as early as the first cycle of chemotherapy, then the relatively high cost associated with the modality may be outweighed by the potential cost savings from avoiding multiple additional cycles of ineffective chemotherapy and associated potential chemotoxicity. Out-of-pocket costs associated with imaging evaluation were also a concern among patients according to our Key Informants. The associated direct and indirect costs of PET/CT compared with conventional imaging should be examined in parallel with outcomes of future studies in order to determine the true value of different imaging modalities for evaluating treatment response among metastatic breast cancer patients.

## Next Steps

Key Informants identified future research needs in several areas that they thought would have large impacts on clinical decisionmaking regarding imaging for treatment evaluation of metastatic breast cancer. Ideally, a treatment evaluation tool would, within days or weeks of beginning treatment, be able to accurately and noninvasively detect whether the treatment was reducing cancer burden without exposing women to potentially harmful side effects such as contrast reactions or ionizing radiation. Such a tool (e.g., a blood test) would ideally be inexpensive, readily accessible to women with metastatic breast cancer, and potentially replace the need for imaging evaluation for treatment response.

### Intermediate and Long-Term Outcomes

Several Key Informants were interested in research that examines clinical and patient-centered outcomes to determine the impact that choice of imaging technologies has on survival, treatment selection, cost, and quality of life. Key Informants were also interested in examining how often more advanced imaging (e.g., PET/CT scans) should be conducted to evaluate treatment in order to lead to the best intermediate and long-term outcomes. Additionally, we did not find any evidence in the published literature about the extent of imaging that is ideal during treatment. For example, if only one site of metastasis is found in initial imaging, should future imaging for treatment evaluation include other potential sites of metastasis to document treatment failure and further spread of disease? Because metastatic breast cancer cannot be cured, the ultimate goal of treatment is to prolong survival with the least reduction in quality of life. Ideally, research into intermediate and long-term outcomes would identify imaging that indicates when treatments are not working as soon as possible so treatment can be stopped, potentially toxic side effects can be minimized, and other forms of treatment can be pursued.

One potential research design that could answer such questions would be to randomize women with metastatic breast cancer to different imaging regimens prior to beginning treatment with followup imaging using the same modalities and imaging protocols at varying time intervals to assess how the modality and timing of imaging affects outcomes. To minimize confounding, randomization could be multi-pronged to account for important clinical differences. For example, randomization could be done separately depending on estrogen receptor status since women with estrogen receptor-positive disease typically have longer survival times and may benefit from different imaging regimens compared with women with estrogen receptor-negative disease. Women would be followed until death or 3 years after diagnosis and cancer recurrences and treatment selections could be assessed from electronic medical records. Additionally, all costs incurred during the followup period could be compared between the different imaging arms. Women could also be surveyed at 6-month intervals to assess quality of life. The time and cost that would be necessary to conduct such a study would be substantial and confounding factors, such as patient and physician imaging and treatment preferences, might make a traditional, multi-institution randomized trial methodologically difficult.

Alternative approaches to examining intermediate and long-term patient-centered outcomes include the use of more adaptive trial designs, such as a pragmatic trial design that allows greater freedom regarding patient and physician imaging and treatment decisions. Even a prospective observational study design involving multiple institutions would provide valuable information regarding the effects of imaging modalities and the frequency of imaging on outcomes. A quality-of-life survey instrument can be easily implemented in either the pragmatic trial or prospective observational study designs to capture patient perspectives on treatment evaluation by imaging. Finally, decision analysis and simulation modeling may have a critical role in estimating the effects of imaging modality and frequency on the intermediate and long-term outcomes for metastatic patients given the time and cost barriers for performing traditional randomized trials.

### Improving Communication With Patients

Studies that focus on improving communication with patients regarding imaging for the purpose of assessing treatment for metastatic breast cancer would be of interest. One option to begin to explore this topic would be to convene focus groups of women who are currently undergoing or have recently completed treatment for metastatic breast cancer and ask targeted questions about their patient-physician communication experiences about imaging. These groups could help researchers gain understanding about the particular research questions that are important to this patient population and would identify the key patient-centered outcomes that should be studied through the aforementioned potential study designs.

For instance, Key Informants were relatively less concerned about ionizing radiation exposure from advanced imaging than initially expected. It is uncertain whether this sentiment is more widespread, or if there remain a large number of patients and providers who are concerned about potential radiation risks. An area of improved communication with patients and providers, therefore, would be to increase stakeholder awareness of the innovative, dose-lowering technologies that have been implemented over the last several years to minimize potential harm from radiation associated with CT, PET, and bone scans. These technologies include automatic exposure control and iterative reconstruction of CT images, as well as advanced electronics in imaging data acquisition systems that limit exposure time. Overall, greater communication between providers and patients may be required to clarify the balance between the benefits and harms of imaging during the informed consent process.

### Personalized Medicine

Key Informants were also interested in imaging that could characterize tumors at the genetic or proteomic level and allow treatments to be specific to particular types of breast cancer, given that breast cancer is a heterogenous disease. Truly personalized imaging for treatment response would require further development of new radiotracers specific to the biological nature of individual breast cancers. More rigorous evaluation of novel radiotracers such as FES and FLT are needed to determine their comparative effectiveness to standard FDG use with PET/CT in specific patient subpopulations.

### Blood Tests To Evaluate Treatment

Several Key Informants indicated that research on biomarkers that could evaluate treatment response and obviate the need for imaging would be greatly useful. There is currently insufficient evidence regarding CTCs and whether their measurement can help predict survival time for metastatic breast cancer patients. There is also insufficient evidence regarding whether measuring such blood tumor markers can guide treatment choices for metastatic breast cancer better than current use of advanced imaging modalities. Future research efforts should focus on the comparative predictive power of CTCs for treatment response and survival versus PET/CT and/or anatomic imaging for treatment response.