# Methods

## Overview

This technical brief combined systemic literature review approaches with Internet searches and Key Informant structured interviews and discussions.

## Search Strategy

We first used broad search terms including Medical Subject Heading terms and key words related to imaging, metastatic breast cancer, and treatment evaluation. We conducted focused searches of PubMed^®^ and the Cochrane Library. An experienced research librarian assisted us in choosing the search terms and limits (Appendix A). We also reviewed the reference lists of identified publications and added previously unidentified papers.

From these identified articles, we excluded publications that were beyond the scope of the technical brief (letters, comments, editorials, news, nonhuman studies, and articles not in English). Because imaging technologies are rapidly evolving, we excluded studies published prior to 2003. Searches were also conducted in a number of imaging and oncologic websites, including the American Society for Clinical Oncology, the American College of Radiology, the American Cancer Society, the National Comprehensive Cancer Network, and the Society for Nuclear Medicine. We also searched ClinicalTrials.gov, NIH Reporter, and ProQuest Dissertations and Theses to find unpublished studies. As in the published literature search, we excluded gray literature sources that were published prior to 2003, those that pertained to animal studies, and those that were not in English.

## Eligibility Criteria

The inclusion and exclusion criteria are presented in Table 1. All titles and abstracts identified through searches were reviewed against our inclusion/exclusion criteria. For studies without adequate information to make a determination, we retrieved full-text articles and reviewed them against the inclusion/exclusion criteria.

Table 1 Inclusion and exclusion criteria for imaging of metastatic breast cancer published literature search

Criterion | Inclusion | Exclusion
Population | Age 19 and above Females Diagnosed with metastatic (stage IV) breast cancer (initial diagnosis or recurrence) | Age 18 and below Males Diagnosed with stages I−III breast cancer Nonhuman
Indication for imaging | Imaging for treatment evaluation | Diagnostic imaging Imaging used to assess stage Imaging used to detect recurrence following successful treatment
Comparator | Comparison of multiple imaging modalities Tumor biomarkers No comparator | None
Outcomes associated with imaging findings | Tumor response Changes in treatment decisions Changes in patient decisions Recurrence-free survival Overall survival Quality of life Cost and resource utilization Adverse events | None
Timing | Published 2003−2013 | Published 2002 or earlier
Setting | All care settings | None
Study design | Systematic reviews Randomized control trials Nonrandomized control trials Cohort studies (prospective and retrospective) Case-control studies Case series | Case reports Opinions Commentaries Letters to the editor with no primary data
Other | English language | Non-English language

Two team members (LG and CL) abstracted data from the published studies to provide an overview of the state of the science by collecting the following information:

- Study setting and geographic location
- Research design and methods
- Type(s) of imaging
- Breast cancer inclusion criteria
- Tumor factors (e.g., whether metastatic tumors were initially diagnosed or were recurrences)
- Comparators used
- Length of followup
- Outcomes associated with imaging findings (accurate detection of tumor response, changes in treatment decisions, prediction for survival, resource utilization, and adverse events).

We limited our data abstraction to studies dealing with imaging used to evaluate treatment response, and therefore did not identify any studies where imaging was an add-on or replacement for some other diagnostic tool aimed at treatment evaluation, or any studies where imaging was used for triaging patients for a future diagnostic test. Furthermore, we excluded studies that examined imaging that was used to detect recurrence after treatment had ended.

## Key Informant Discussions

We worked with the Key Informants to understand current imaging utilization practices, emerging technologies, research in progress, patient values, and study design issues, in order to help summarize the current state of the science and inform future research on imaging for treatment evaluation for women with metastatic breast cancer. We identified Key Informants including clinical experts/practitioners in radiology and oncology, as well as representatives of the patient perspective, product purchaser, and the device industry. Despite multiple attempts to identify a Key Informant to provide the perspective of health care entities that finance or reimburse for health costs, we could not identify one who was willing to serve in this capacity. Key Informants were identified through informal consultations with local, national, and international experts in breast cancer and imaging technologies. While we attempted to schedule more than one Key Informant per teleconference, most (n=5) calls consisted of only one Key Informant. Calls were led by one of several team members and at least two other team members participated. All calls were recorded for reference.

Initially, we asked the Key Informants to create a comprehensive list of imaging technologies, including technologies that are not commonly used or in development and may be used in the United States in the near future. We also asked them to identify the advantages and disadvantages and appropriateness of utilization of each type of imaging. Key Informants were asked to identify factors surrounding imaging decisions, including clinical guidelines, reimbursement policies, setting (e.g., tertiary care vs. community hospital), and patient preferences. The Key Informants also provided information about factors that patients consider when discussing imaging decisions with their providers such as test accuracy and invasiveness, safety issues, and out-of-pocket costs.