# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Leah Hole-Marshall, J.D.
  Washington State Department of Labor and Industries
  Olympia, WA
- Hannah Linden, M.D.
  University of Washington
  Seattle, WA
- Josh Morse, M.P.H.
  Washington State Health Care Authority
  Olympia, WA
- Nina Mortazavi-Jehanno
  Hôpital Rene Huguenin
  Saint-Cloud, France
- Robert Nordstrom, Ph.D.
  National Cancer Institute
  Bethesda, MD
- Habib Rahbar, M.D.
  University of Washington
  Seattle, WA