# Key Informants

In designing the study questions, the EPC consulted a panel of Key Informants who represent subject experts and end-users of research. Key Informant input can inform key issues related to the topic of the technical brief. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches and/or conclusions do not necessarily represent the views of individual Key Informants or their organizations.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Richard Frank, M.D., Ph.D.
  Siemens Medical Solutions
  Malvern, PA
- John Hennessy
  Sarah Cannon
  Kansas City, MO
- Jeff Hersh, Ph.D., M.D.
  GE Healthcare
  Wauwatosa, WI
- Janie Lee, M.D., M.Sc.
  University of Washington
  Seattle, WA
- Constance Lehman, M.D., Ph.D.
  University of Washington
  Seattle, WA
- Gary Lyman, M.D., M.P.H.
  Fred Hutchinson Cancer and Research Center
  Seattle, WA
- David Mankoff, M.D., Ph.D.
  University of Pennsylvania
  Philadelphia, PA
- Joanne Mortimer, M.D.
  City of Hope
  Duarte, CA
- Mary Lou Smith, J.D., M.B.A.
  Research Advocacy Network
  Chicago, IL