# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Paul Kraegel, Elaine Graham, Andrew Hamilton, and Leah Williams.