# Background

## Introduction

In spite of significant gains in detection and treatment, breast cancer continues to have a broad impact in the United States, with an estimated 234,580 individuals with new diagnoses in 2013.^1^ About 33 percent of individuals with breast cancer diagnosed between 2001 and 2007 had regional metastases, with a 5-year relative survival rate of 84 percent. Approximately 5 percent were diagnosed with distant metastases, most commonly to the bones, lungs, liver, or brain, and had a 5-year relative survival rate of only 23 percent.1

Several imaging modalities, including magnetic resonance imaging (MRI), computed tomography (CT), positron emission tomography (PET), PET/CT, and bone scintigraphy, are used to evaluate the effects of treatment for metastatic breast cancer.2 However, as outlined in guidelines from the National Comprehensive Cancer Network and the National Institute for Health and Clinical Excellence, evidence regarding the accuracy and effectiveness of these modalities to evaluate treatment of metastatic breast cancer is lacking, even though the types and results of imaging may strongly affect patient outcomes.2,3 Inappropriate use could lead to overtreatment. For example, use of CT during treatment response monitoring may show morphologic or size changes in the tumor in the setting of nonresponse, leading to continued ineffective and potentially toxic chemotherapy. Alternatively, inappropriate use of imaging may lead to undertreatment if foci of enlarging metastatic disease are not identified on CT and these lead to disease progression. Furthermore, imaging modalities vary substantially in cost, ranging in direct costs from about $250 for a bone scan to $1,114 for PET/CT,4,5 underscoring the need to understand whether more expensive tests result in improved patient outcomes.

## Current Practices in Imaging Metastatic Breast Cancer

In general, following diagnosis of metastatic breast cancer and initiation of treatment, women receive imaging about every 2–4 months in order to determine whether their tumor burden is improving. Since there are no reliable biomarkers to help determine response to treatment, oncologists are currently reliant mostly on visual detection of gross changes seen on imaging to guide treatment decisions. If imaging reveals that their cancer is progressing or is unchanged, alternative treatment regimens may be pursued. Although metastatic breast cancer is not curable, the goal of treatment is to prolong survival and reduce symptoms in order to maximize quality of life. Health care providers generally rely on recommendations from professional societies such as the National Comprehensive Cancer Network, the American Society for Clinical Oncology, and the European Society for Medical Oncology to guide the use of imaging techniques to assess treatment response in metastatic breast cancer. However, these recommendations are generally based on data that are not specific to assessing treatment in the metastatic breast cancer population. Current practice recommendations for managing metastatic breast cancer include imaging of the chest, abdomen, and bone in addition to obtaining medical histories, physical examinations, and relevant laboratory tests.6,7 The most commonly used imaging modalities for treatment evaluation of metastatic breast cancer are chest/abdomen/pelvis CT and PET/CT.6,7 For patients with bone-only metastases, bone scans are the most common imaging modality, with supplemental use of CT, MRI, and/or PET/CT to evaluate localized symptoms.7,8

## Objective of This Technical Brief

Although multiple imaging modalities for treatment evaluation for metastatic breast cancer are used clinically, their comparative effectiveness in terms of health outcomes, patient satisfaction, and cost, has not been determined. The purpose of this technical brief is to understand current imaging utilization, emerging technologies, research in progress, patient values, and study design issues, in order to summarize the current state of the science and inform future research in this area. We evaluated whether imaging technologies were utilized differently among subpopulations and whether outcomes varied by subpopulations. We also evaluated the potential role of novel biomarkers in imaging for treatment evaluation of metastatic breast cancer. We combined information we obtained from published literature, gray literature, and Key Informants in order to provide the context for appropriate comparative effectiveness studies on imaging for treatment evaluation for metastatic breast cancer in the near future.

## Guiding Questions

The questions below guided the data collection for this technical brief. Question 1 lays the groundwork for the literature review by describing each of the imaging modalities currently in use for treatment evaluation for metastatic breast cancer. We describe the accuracy, potential benefits, and potential risks of each modality, including safety, costs, adverse effects, and other issues. Question 2 provides the context for how each of the imaging modalities is currently used, including U.S. Food and Drug Administration (FDA) approval status, need for additional equipment (e.g., contrast agents), and, when possible, we describe reimbursement policies and how commonly each modality is used for metastatic breast cancer treatment evaluation. Using published studies and gray literature, Question 3 explores the state of the current research on the use and safety of each imaging modality. Finally, in Question 4, we identify important issues pertaining to metastatic breast cancer imaging, particularly areas of uncertainty surrounding ethical, economic, and safety issues, as well as areas of research that we expect to be pursued in the near future.

### Guiding Question 1 Overview of Imaging Modalities Currently Used To Evaluate Treatment of Metastatic Breast Cancer

- What are the imaging modalities currently used for metastatic breast cancer treatment evaluation in the United States?
- What are the advantages, disadvantages, safety issues and relative costs of each modality?

### Guiding Question 2 Context in Which Imaging Modalities Are Currently Used To Evaluate Treatment of Metastatic Breast Cancer

- What modalities have received FDA approval?
- What other resources (e.g., contrast agents, tracers) are commonly used with each modality?
- How commonly is each modality used?

### Guiding Question 3 Current Evidence for Each Imaging Modality

- What published and unpublished studies have reported on the use and safety of each modality?

### Guiding Question 4 Important Issues and Future Directions of Metastatic Breast Cancer Imaging for Treatment Evaluation

- Given the current state of the science, what are the implications for future diffusion of the imaging modalities for treatment evaluation of metastatic breast cancer?
- What are the economic, ethical, and privacy considerations that impact the diffusion of each imaging modality?
- What are important areas of uncertainty for metastatic breast cancer imaging modalities?
- What research questions would have the greatest individual and societal impact (e.g., in terms of how imaging for treatment evaluation affects survival time, quality of life, and health care utilization) for the population of women with metastatic breast cancer?