# Calculation of Estimate of Number of Women Receiving Imaging for Treatment Evaluation of Metastatic Breast Cancer

We estimated that the U.S. prevalence of women with metastatic breast cancer is about 160,000, with a median survival time of about 2 years.^1^ Our Key Informants estimated that about 90 percent of women with metastatic breast cancer receive some type of chemotherapy and that treatment for metastatic breast cancer typically lasts about 1 year. We estimated that about half of the 160,000 women, or about 80,000 women, would be in the first year of their metastatic breast cancer diagnosis and would be candidates for receiving treatment, and 90 percent of these, or 72,000, would be receiving chemotherapy and thus imaging for treatment evaluations per year. Our literature search covered 11 years, so 72,000*11=792,000 women received scans for treatment evaluation of metastatic breast cancer.

1 Metastatic Breast Cancer Network. Education: Prevalence of Metastatic Breast Cancer. 2013. http://mbcn.org/education/category/prevalence/. December 16, 2013. .