# Literature Flow Diagram

This figure is a literature flow diagram that summarizes the search and selection of articles related to Imaging Techniques for Treatment Evaluation for Metastatic Breast Cancer. Through database searching, 159 citations to potentially relevant articles were identified, and the full text of these articles was assessed for eligibility. Of these 159 articles, 17 met inclusion criteria and were included. The reasons for exclusion of 142 full-text articles were: nonhuman studies (3); letter to the editor (1); did not address use of imaging for treatment evaluation of metastatic breast cancer (118); did not include metastatic breast cancer patients (10); described PET scans conducted 1990-1994 using tracer MET, now obsolete (1); described diagnostic breast imaging, not imaging for treatment evaluation (4); imaging to monitor cancer recurrence, not treatment evaluation (1); addressed diagnosing brain metastases, not evaluating treatment of metastatic breast cancer (1); review articles for which citations were reviewed for additional relevant articles (3).