# List of Excluded Published Literature Studies

Number | Citation | Reason for Exclusion
1 | Agarwal A, Munoz-Najar U, Klueh U, et al. N-acetyl-cysteine promotes angiostatin production and vascular collapse in an orthotopic model of breast cancer. Am J Pathol. 2004 May;164(5):1683-96. PMID: 15111315. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
2 | Akazawa K, Tamaki Y, Taguchi T, et al. Potential of reduction in total tumor volume measured with 3D-MRI as a prognostic factor for locally-advanced breast cancer patients treated with primary chemotherapy. Breast J. 2008 Nov-Dec;14(6):523-31. PMID: 19000056. | Article did not include metastatic breast cancer patients.
3 | Ali AM, Ueno T, Tanaka S, et al. Determining circulating endothelial cells using CellSearch system during preoperative systemic chemotherapy in breast cancer patients. Eur J Cancer. 2011 Oct;47(15):2265-72. PMID: 21737256. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
4 | Altenburg JD, Siddiqui RA. Omega-3 polyunsaturated fatty acids down-modulate CXCR4 expression and function in MDA-MB-231 breast cancer cells. Mol Cancer Res. 2009 Jul;7(7):1013-20. PMID: 19567784. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
5 | Apple SK, Matin M, Olsen EP, et al. Significance of lobular intraepithelial neoplasia at margins of breast conservation specimens: a report of 38 cases and literature review. Diagn Pathol. 2010;5:54. PMID: 20727142. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
6 | Asakura H, Takashima H, Mitani M, et al. Unknown primary carcinoma, diagnosed as inflammatory breast cancer,and successfully treated with trastuzumab and vinorelbine. Int J Clin Oncol. 2005 Aug;10(4):285-8. PMID: 16136377. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
7 | Bangash AK, Atassi B, Kaklamani V, et al. 90Y radioembolization of metastatic breast cancer to the liver: toxicity, imaging response, survival. J Vasc Interv Radiol. 2007 May;18(5):621-8. PMID: 17494843. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
8 | Barth RJ, Jr., Gibson GR, Carney PA, et al. Detection of breast cancer on screening mammography allows patients to be treated with less-toxic therapy. AJR Am J Roentgenol. 2005 Jan;184(1):324-9. PMID: 15615996. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
9 | Bauerle T, Bartling S, Berger M, et al. Imaging anti-angiogenic treatment response with DCE-VCT, DCE-MRI and DWI in an animal model of breast cancer bone metastasis. Eur J Radiol. 2010 Feb;73(2):280-7. PMID: 19070445. | Non-human study.
10 | Bauerle T, Hilbig H, Bartling S, et al. Bevacizumab inhibits breast cancer-induced osteolysis, surrounding soft tissue metastasis, and angiogenesis in rats as visualized by VCT and MRI. Neoplasia. 2008 May;10(5):511-20. PMID: 18472968. | Non-human study.
11 | Biersack HJ, Bender H, Palmedo H. FDG-PET in monitoring therapy of breast cancer. Eur J Nucl Med Mol Imaging. 2004 Jun;31 Suppl 1:S112-7. PMID: 15112111. | Review article. Reviewed citations for additional relevant articles.
12 | Boccardo FM, Casabona F, Friedman D, et al. Surgical prevention of arm lymphedema after breast cancer treatment. Ann Surg Oncol. 2011 Sep;18(9):2500-5. PMID: 21369739. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
13 | Bondareva A, Downey CM, Ayres F, et al. The lysyl oxidase inhibitor, beta-aminopropionitrile, diminishes the metastatic colonization potential of circulating breast cancer cells. PLoS One. 2009;4(5):e5620. PMID: 19440335. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
14 | Bricou A, Duval MA, Charon Y, et al. Mobile gamma cameras in breast cancer care - a review. Eur J Surg Oncol. 2013 May;39(5):409-16. PMID: 23465183. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
15 | Brown-Glaberman U, Graham A, Stopeck A. A case of metaplastic carcinoma of the breast responsive to chemotherapy with Ifosfamide and Etoposide: improved antitumor response by targeting sarcomatous features. Breast J. 2010 Nov-Dec;16(6):663-5. PMID: 21070449. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
16 | Bullitt E, Lin NU, Ewend MG, et al. Tumor therapeutic response and vessel tortuosity: preliminary report in metastatic breast cancer. Med Image Comput Comput Assist Interv. 2006;9(Pt 2):561-8. PMID: 17354817. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
17 | Burkholder HC, Witherspoon LE, Burns RP, et al. Breast surgery techniques: preoperative bracketing wire localization by surgeons. Am Surg. 2007 Jun;73(6):574-8; discussion 8-9. PMID: 17658094. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
18 | Caralt M, Bilbao I, Cortes J, et al. Hepatic resection for liver metastases as part of the "oncosurgical" treatment of metastatic breast cancer. Ann Surg Oncol. 2008 Oct;15(10):2804-10. PMID: 18670821. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
19 | Castro Pena P, Kirova YM, Campana F, et al. Anatomical, clinical and radiological delineation of target volumes in breast cancer radiotherapy planning: individual variability, questions and answers. Br J Radiol. 2009 Jul;82(979):595-9. PMID: 19255114. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
20 | Chen JH, Mehta RS, Nalcioglu O, et al. Inflammatory breast cancer after neoadjuvant chemotherapy: can magnetic resonance imaging precisely diagnose the final pathological response? Ann Surg Oncol. 2008 Dec;15(12):3609-13. PMID: 18807091. | Article about diagnostic breast imaging, not imaging for treatment evaluation.
21 | Cheung YC, Chen SC, Ueng SH, et al. Dynamic enhanced computed tomography values of locally advanced breast cancers predicting axilla nodal metastasis after neoadjuvant chemotherapy. J Comput Assist Tomogr. 2009 May-Jun;33(3):422-5. PMID: 19478638. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
22 | Conrado-Abrao F, Das-Neves-Pereira JC, Fernandes A, et al. Thoracoscopic approach in the treatment of breast cancer relapse in the internal mammary lymph node. Interact Cardiovasc Thorac Surg. 2010 Sep;11(3):328-30. PMID: 20576656. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
23 | Dalus K, Reitsamer R, Holzmannhofer J, et al. Lymphoscintigraphy in breast cancer patients after neoadjuvant chemotherapy. Diagnostic value and the work-up of sentinel node negative patients. Nuklearmedizin. 2011;50(1):33-8. PMID: 21336417. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
24 | De Los Santos J, Bernreuter W, Keene K, et al. Accuracy of breast magnetic resonance imaging in predicting pathologic response in patients treated with neoadjuvant chemotherapy. Clin Breast Cancer. 2011 Oct;11(5):312-9. PMID: 21831721. | Article did not include metastatic breast cancer patients.
25 | Donadio M, Ardine M, Berruti A, et al. Weekly cisplatin plus capecitabine in metastatic breast cancer patients heavily pretreated with both anthracycline and taxanes. Oncology. 2005;69(5):408-13. PMID: 16319512. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
26 | Driul L, Bernardi S, Bertozzi S, et al. New surgical trends in breast cancer treatment: conservative interventions and oncoplastic breast surgery. Minerva Ginecol. 2013 Jun;65(3):289-96. PMID: 23689171. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
27 | Dunnwald LK, Gralow JR, Ellis GK, et al. Tumor metabolism and blood flow changes by positron emission tomography: relation to survival in patients treated with neoadjuvant chemotherapy for locally advanced breast cancer. J Clin Oncol. 2008 Sep 20;26(27):4449-57. PMID: 18626006. | Article did not include metastatic breast cancer patients.
28 | El-Mabhouh AA, Nation PN, Abele JT, et al. A conjugate of gemcitabine with bisphosphonate (Gem/BP) shows potential as a targeted bone-specific therapeutic agent in an animal model of human breast cancer bone metastases. Oncol Res. 2011;19(6):287-95. PMID: 21776824. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
29 | Eubank WB, Mankoff DA. Evolving role of positron emission tomography in breast cancer imaging. Semin Nucl Med. 2005 Apr;35(2):84-99. PMID: 15765372. | Review article. Reviewed citations for additional relevant articles.
30 | Fanale MA, Uyei AR, Theriault RL, et al. Treatment of metastatic breast cancer with trastuzumab and vinorelbine during pregnancy. Clin Breast Cancer. 2005 Oct;6(4):354-6. PMID: 16277887. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
31 | Fischer U, Baum F, Luftner-Nagel S. Preoperative MR imaging in patients with breast cancer: preoperative staging, effects on recurrence rates, and outcome analysis. Magn Reson Imaging Clin N Am. 2006 Aug;14(3):351-62, vi. PMID: 17098176. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
32 | Fong S, Itahana Y, Sumida T, et al. Id-1 as a molecular target in therapy for breast cancer cell invasion and metastasis. Proc Natl Acad Sci U S A. 2003 Nov 11;100(23):13543-8. PMID: 14578451. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
33 | Gatcombe HG, Olson TA, Esiashvili N. Metastatic primary angiosarcoma of the breast in a pediatric patient with a complete response to systemic chemotherapy and definitive radiation therapy: case report and review of the literature. J Pediatr Hematol Oncol. 2010 Apr;32(3):192-4. PMID: 20186104. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
34 | Gennari A, Piccardo A, Altrinetti V, et al. Whither the PET scan? The role of PET imaging in the staging and treatment of breast cancer. Curr Oncol Rep. 2012 Feb;14(1):20-6. PMID: 22094933. | Review article. Reviewed citations for additional relevant articles.
35 | Gerber B, Heintze K, Stubert J, et al. Axillary lymph node dissection in early-stage invasive breast cancer: is it still standard today? Breast Cancer Res Treat. 2011 Aug;128(3):613-24. PMID: 21523451. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
36 | Giacalone PL, Bourdon A, Trinh PD, et al. Radioguided occult lesion localization plus sentinel node biopsy (SNOLL) versus wire-guided localization plus sentinel node detection: a case control study of 129 unifocal pure invasive non-palpable breast cancers. Eur J Surg Oncol. 2012 Mar;38(3):222-9. PMID: 22231127. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
37 | Giglio P, Tremont-Lukats IW, Groves MD. Response of neoplastic meningitis from solid tumors to oral capecitabine. J Neurooncol. 2003 Nov;65(2):167-72. PMID: 14686737. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
38 | Gilardi L, Paganelli G. Is a SUV cut-off necessary in the evaluation of the response of axillary lymph node metastases to neoadjuvant therapy? Eur J Nucl Med Mol Imaging. 2010 Nov;37(11):2202. PMID: 20821210. | Letter to the editor.
39 | Goldoni S, Seidler DG, Heath J, et al. An antimetastatic role for decorin in breast cancer. Am J Pathol. 2008 Sep;173(3):844-55. PMID: 18688028. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
40 | Goyal S, Puri T, Julka PK, et al. Excellent response to letrozole in brain metastases from breast cancer. Acta Neurochir (Wien). 2008 Jun;150(6):613-4; discussion 4-5. PMID: 18458809. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
41 | Grabau D, Dihge L, Ferno M, et al. Completion axillary dissection can safely be omitted in screen detected breast cancer patients with micrometastases. A decade's experience from a single institution. Eur J Surg Oncol. 2013 Jun;39(6):601-7. PMID: 23579175. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
42 | Gralow JR, Biermann JS, Farooki A, et al. NCCN Task Force Report: Bone Health in Cancer Care. J Natl Compr Canc Netw. 2009 Jun;7 Suppl 3:S1-32; quiz S3-5. PMID: 19555589. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
43 | Hayashi H, Kimura M, Yoshimoto N, et al. A case of HER2-positive male breast cancer with lung metastases showing a good response to trastuzumab and paclitaxel treatment. Breast Cancer. 2009;16(2):136-40. PMID: 18548321. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
44 | Hill KL, Jr., Lipson AC, Sheehan JM. Brain magnetic resonance imaging changes after sorafenib and sunitinib chemotherapy in patients with advanced renal cell and breast carcinoma. J Neurosurg. 2009 Sep;111(3):497-503. PMID: 19199506. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
45 | Hiraga T, Williams PJ, Ueda A, et al. Zoledronic acid inhibits visceral metastases in the 4T1/luc mouse breast cancer model. Clin Cancer Res. 2004 Jul 1;10(13):4559-67. PMID: 15240548. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
46 | Hsiang DJ, Yamamoto M, Mehta RS, et al. Predicting nodal status using dynamic contrast-enhanced magnetic resonance imaging in patients with locally advanced breast cancer undergoing neoadjuvant chemotherapy with and without sequential trastuzumab. Arch Surg. 2007 Sep;142(9):855-61; discussion 60-1. PMID: 17875840. | Article did not include metastatic breast cancer patients.
47 | Hu Z, Gerseny H, Zhang Z, et al. Oncolytic adenovirus expressing soluble TGFbeta receptor II-Fc-mediated inhibition of established bone metastases: a safe and effective systemic therapeutic approach for breast cancer. Mol Ther. 2011 Sep;19(9):1609-18. PMID: 21712815. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
48 | Hua F, Feng X, Guan Y, et al. Non-Hodgkin's lymphoma of supraclavicular lymph nodes can mimic metastasis of breast cancer during chemotherapy on FDG PET/CT. Clin Nucl Med. 2009 Sep;34(9):594-5. PMID: 19692820. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
49 | Huyn ST, Burton JB, Sato M, et al. A potent, imaging adenoviral vector driven by the cancer-selective mucin-1 promoter that targets breast cancer metastasis. Clin Cancer Res. 2009 May 1;15(9):3126-34. PMID: 19366829. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
50 | Intra M, Trifiro G, Viale G, et al. Second biopsy of axillary sentinel lymph node for reappearing breast cancer after previous sentinel lymph node biopsy. Ann Surg Oncol. 2005 Nov;12(11):895-9. PMID: 16195833. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
51 | Isola V, Pece A, Pierro L. Photodynamic therapy with verteporfin of choroidal malignancy from breast cancer. Am J Ophthalmol. 2006 Nov;142(5):885-7. PMID: 17056382. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
52 | Javid S, Segara D, Lotfi P, et al. Can breast MRI predict axillary lymph node metastasis in women undergoing neoadjuvant chemotherapy. Ann Surg Oncol. 2010 Jul;17(7):1841-6. PMID: 20143266. | Article about diagnostic breast imaging, not imaging for treatment evaluation.
53 | Jones MD, Liu JC, Barthel TK, et al. A proteasome inhibitor, bortezomib, inhibits breast cancer growth and reduces osteolysis by downregulating metastatic genes. Clin Cancer Res. 2010 Oct 15;16(20):4978-89. PMID: 20843837. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
54 | Jones RL, Berry GJ, Rubens RD, et al. Clinical and pathological absence of cardiotoxicity after liposomal doxorubicin. Lancet Oncol. 2004 Sep;5(9):575-7. PMID: 15337488. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
55 | Kaliki S, Shields CL, Al-Dahmash SA, et al. Photodynamic therapy for choroidal metastasis in 8 cases. Ophthalmology. 2012 Jun;119(6):1218-22. PMID: 22386261. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
56 | Katalinic D, Stern-Padovan R, Ivanac I, et al. Symptomatic cardiac metastases of breast cancer 27 years after mastectomy: a case report with literature review--pathophysiology of molecular mechanisms and metastatic pathways, clinical aspects, diagnostic procedures and treatment modalities. World J Surg Oncol. 2013;11:14. PMID: 23343205. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
57 | Kelemen G, Uhercsak G, Ormandi K, et al. Long-term efficiency and toxicity of adjuvant dose-dense sequential adriamycin-Paclitaxel-cyclophosphamide chemotherapy in high-risk breast cancer. Oncology. 2010;78(3-4):271-3. PMID: 20523088. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
58 | Khalili P, Arakelian A, Chen G, et al. A non-RGD-based integrin binding peptide (ATN-161) blocks breast cancer growth and metastasis in vivo. Mol Cancer Ther. 2006 Sep;5(9):2271-80. PMID: 16985061. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
59 | Kilbride KE, Lee MC, Nees AV, et al. Axillary staging prior to neoadjuvant chemotherapy for breast cancer: predictors of recurrence. Ann Surg Oncol. 2008 Nov;15(11):3252-8. PMID: 18784961. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
60 | Kinhikar RA, Deshpande SS, Mahantshetty U, et al. HDR brachytherapy combined with 3-D conformal vs. IMRT in left-sided breast cancer patients including internal mammary chain: comparative analysis of dosimetric and technical parameters. J Appl Clin Med Phys. 2005 Summer;6(3):1-12. PMID: 16143787. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
61 | Kodack DP, Chung E, Yamashita H, et al. Combined targeting of HER2 and VEGFR2 for effective treatment of HER2-amplified breast cancer brain metastases. Proc Natl Acad Sci U S A. 2012 Nov 6;109(45):E3119-27. PMID: 23071298. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
62 | Koehler KE, Ohlinger R. Sensitivity and specificity of preoperative ultrasonography for diagnosing nodal metastases in patients with breast cancer. Ultraschall Med. 2011 Aug;32(4):393-9. PMID: 20938895. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
63 | Kogure K, Sakurai T, Tsuzuki Y, et al. Long-term survival after hepatectomy for large metastatic breast cancer: a case report. Hepatogastroenterology. 2003 May-Jun;50(51):827-9. PMID: 12828095. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
64 | Kokke MC, Jannink I, Barneveld PC, et al. Incidence of axillary recurrence in 113 sentinel node negative breast cancer patients: a 3-year follow-up study. Eur J Surg Oncol. 2005 Apr;31(3):221-5. PMID: 15780554. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
65 | Koolen BB, Valdes Olmos RA, Elkhuizen PH, et al. Locoregional lymph node involvement on 18F-FDG PET/CT in breast cancer patients scheduled for neoadjuvant chemotherapy. Breast Cancer Res Treat. 2012 Aug;135(1):231-40. PMID: 22872522. | Article about diagnostic breast imaging, not imaging for treatment evaluation.
66 | Kothari MS, Rusby JE, Agusti AA, et al. Sentinel lymph node biopsy after previous axillary surgery: A review. Eur J Surg Oncol. 2012 Jan;38(1):8-15. PMID: 22032909. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
67 | Krainick-Strobel UE, Lichtenegger W, Wallwiener D, et al. Neoadjuvant letrozole in postmenopausal estrogen and/or progesterone receptor positive breast cancer: a phase IIb/III trial to investigate optimal duration of preoperative endocrine therapy. BMC Cancer. 2008;8:62. PMID: 18302747. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
68 | Krak NC, Hoekstra OS, Lammertsma AA. Measuring response to chemotherapy in locally advanced breast cancer: methodological considerations. Eur J Nucl Med Mol Imaging. 2004 Jun;31 Suppl 1:S103-11. PMID: 15103507. | Article did not include metastatic breast cancer patients.
69 | Krukemeyer MG, Wagner W, Jakobs M, et al. Tumor regression by means of magnetic drug targeting. Nanomedicine (Lond). 2009 Dec;4(8):875-82. PMID: 19958224. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
70 | Kubota K, Ogawa Y, Nishigawa T, et al. Tissue harmonic imaging sonography of the axillary lymph nodes: evaluation of response to neoadjuvant chemotherapy in breast cancer patients. Oncol Rep. 2003 Nov-Dec;10(6):1911-4. PMID: 14534717. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
71 | Kumar R, Alavi A. Fluorodeoxyglucose-PET in the management of breast cancer. Radiol Clin North Am. 2004 Nov;42(6):1113-22, ix. PMID: 15488561. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
72 | Labidi SI, Bachelot T, Ray-Coquard I, et al. Bevacizumab and paclitaxel for breast cancer patients with central nervous system metastases: a case series. Clin Breast Cancer. 2009 May;9(2):118-21. PMID: 19433393. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
73 | Latif N, Rana F, Guthrie T. Breast cancer and HIV in the era of highly active antiretroviral therapy: two case reports and review of the literature. Breast J. 2011 Jan-Feb;17(1):87-92. PMID: 21134040. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
74 | Leonard GD, Swain SM. Ductal carcinoma in situ, complexities and challenges. J Natl Cancer Inst. 2004 Jun 16;96(12):906-20. PMID: 15199110. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
75 | Leung JW. Screening mammography reduces morbidity of breast cancer treatment. AJR Am J Roentgenol. 2005 May;184(5):1508-9. PMID: 15855106. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
76 | Li X, Ferrel GL, Guerra MC, et al. Preliminary safety and efficacy results of laser immunotherapy for the treatment of metastatic breast cancer patients. Photochem Photobiol Sci. 2011 May;10(5):817-21. PMID: 21373701. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
77 | Liljegren A, Bergh J, Castany R. Early experience with sunitinib, combined with docetaxel, in patients with metastatic breast cancer. Breast. 2009 Aug;18(4):259-62. PMID: 19744626. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
78 | Lindholm P, Lapela M, Nagren K, et al. Preliminary study of carbon-11 methionine PET in the evaluation of early response to therapy in advanced breast cancer. Nucl Med Commun. 2009 Jan;30(1):30-6. PMID: 19306512. | Although article published in 2009, PET scans done 1990-1994 using tracer MET, which is now obsolete.
79 | Littrup PJ, Jallad B, Chandiwala-Mody P, et al. Cryotherapy for breast cancer: a feasibility study without excision. J Vasc Interv Radiol. 2009 Oct;20(10):1329-41. PMID: 19800542. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
80 | Lu CY, Srasuebkul P, Drew AK, et al. Positive spillover effects of prescribing requirements: increased cardiac testing in patients treated with trastuzumab for HER2+ metastatic breast cancer. Intern Med J. 2012 Nov;42(11):1229-35. PMID: 21981464. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
81 | MacDonald SM, Harisinghani MG, Katkar A, et al. Nanoparticle-enhanced MRI to evaluate radiation delivery to the regional lymphatics for patients with breast cancer. Int J Radiat Oncol Biol Phys. 2010 Jul 15;77(4):1098-104. PMID: 19836160. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
82 | Macia Escalante S, Rodriguez Lescure A, Pons Sanz V, et al. A patient with breast cancer with hepatic metastases and a complete response to herceptin as monotherapy. Clin Transl Oncol. 2006 Oct;8(10):761-3. PMID: 17074677. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
83 | Maffioli L, Florimonte L, Pagani L, et al. Current role of bone scan with phosphonates in the follow-up of breast cancer. Eur J Nucl Med Mol Imaging. 2004 Jun;31 Suppl 1:S143-8. PMID: 15088128. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
84 | Malmstrom P, Holmberg L, Anderson H, et al. Breast conservation surgery, with and without radiotherapy, in women with lymph node-negative breast cancer: a randomised clinical trial in a population with access to public mammography screening. Eur J Cancer. 2003 Aug;39(12):1690-7. PMID: 12888363. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
85 | Mariani G, Erba P, Villa G, et al. Lymphoscintigraphic and intraoperative detection of the sentinel lymph node in breast cancer patients: the nuclear medicine perspective. J Surg Oncol. 2004 Mar;85(3):112-22. PMID: 14991882. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
86 | Menes TS, Kerlikowske K, Jaffer S, et al. Rates of atypical ductal hyperplasia have declined with less use of postmenopausal hormone treatment: findings from the Breast Cancer Surveillance Consortium. Cancer Epidemiol Biomarkers Prev. 2009 Nov;18(11):2822-8. PMID: 19900937. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
87 | Moadel RM, Nguyen AV, Lin EY, et al. Positron emission tomography agent 2-deoxy-2-[18F]fluoro-D-glucose has a therapeutic potential in breast cancer. Breast Cancer Res. 2003;5(6):R199-205. PMID: 14580255. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
88 | Montemurro F, Russo F, Martincich L, et al. Dynamic contrast enhanced magnetic resonance imaging in monitoring bone metastases in breast cancer patients receiving bisphosphonates and endocrine therapy. Acta Radiol. 2004 Feb;45(1):71-4. PMID: 15164782. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
89 | Montgomery DA, Krupa K, Cooke TG. Follow-up in breast cancer: does routine clinical examination improve outcome? A systematic review of the literature. Br J Cancer. 2007 Dec 17;97(12):1632-41. PMID: 18000508. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
90 | Moon HJ, Kim MJ, Kim EK, et al. US surveillance of regional lymph node recurrence after breast cancer surgery. Radiology. 2009 Sep;252(3):673-81. PMID: 19546429. | Article about imaging to monitor cancer recurrence, not treatment evaluation.
91 | Moss S, Waller M, Anderson TJ, et al. Randomised controlled trial of mammographic screening in women from age 40: predicted mortality based on surrogate outcome measures. Br J Cancer. 2005 Mar 14;92(5):955-60. PMID: 15726103. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
92 | Nagashima T, Sakakibara M, Kadowaki M, et al. Response rate to neoadjuvant chemotherapy measured on imaging predicts early recurrence and death in breast cancer patients with lymph node involvements. Acta Radiol. 2011 Apr 1;52(3):241-6. PMID: 21498357. | Article did not include metastatic breast cancer patients.
93 | Nakamura H, Kawasaki N, Taguchi M, et al. Reconstruction of the anterior chest wall after subtotal sternectomy for metastatic breast cancer: report of a case. Surg Today. 2007;37(12):1083-6. PMID: 18030570. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
94 | Newman LA. Local control of ductal carcinoma in situ based on tumor and patient characteristics: the surgeon's perspective. J Natl Cancer Inst Monogr. 2010;2010(41):152-7. PMID: 20956822. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
95 | Newstead GM. MR imaging in the management of patients with breast cancer. Semin Ultrasound CT MR. 2006 Aug;27(4):320-32. PMID: 16916000. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
96 | Newton-Northup JR, Dickerson MT, Ma L, et al. Inhibition of metastatic tumor formation in vivo by a bacteriophage display-derived galectin-3 targeting peptide. Clin Exp Metastasis. 2013 Feb;30(2):119-32. PMID: 22851004. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
97 | Ngo C, Pollet AG, Laperrelle J, et al. Intraoperative ultrasound localization of nonpalpable breast cancers. Ann Surg Oncol. 2007 Sep;14(9):2485-9. PMID: 17541694. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
98 | Nirmala S, Krishnaswamy M, Janaki MG, et al. Unilateral solitary choroid metastasis from breast cancer: rewarding results of external radiotherapy. J Cancer Res Ther. 2008 Oct-Dec;4(4):206-8. PMID: 19052398. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
99 | Ono M, Ando M, Yunokawa M, et al. Brain metastases in patients who receive trastuzumab-containing chemotherapy for HER2-overexpressing metastatic breast cancer. Int J Clin Oncol. 2009 Feb;14(1):48-52. PMID: 19225924. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
100 | Orgera G, Curigliano G, Krokidis M, et al. High-intensity focused ultrasound effect in breast cancer nodal metastasis. Cardiovasc Intervent Radiol. 2010 Apr;33(2):447-9. PMID: 20162283. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
101 | Park SH, Kim MJ, Park BW, et al. Impact of preoperative ultrasonography and fine-needle aspiration of axillary lymph nodes on surgical management of primary breast cancer. Ann Surg Oncol. 2011 Mar;18(3):738-44. PMID: 20890729. | Article about diagnostic breast imaging, not imaging for treatment evaluation.
102 | Pass H, Vicini FA, Kestin LL, et al. Changes in management techniques and patterns of disease recurrence over time in patients with breast carcinoma treated with breast-conserving therapy at a single institution. Cancer. 2004 Aug 15;101(4):713-20. PMID: 15305400. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
103 | Pavic D, Koomen MA, Kuzmiak CM, et al. The role of magnetic resonance imaging in diagnosis and management of breast cancer. Technol Cancer Res Treat. 2004 Dec;3(6):527-41. PMID: 15560710. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
104 | Port ER, Yeung H, Gonen M, et al. 18F-2-fluoro-2-deoxy-D-glucose positron emission tomography scanning affects surgical management in selected patients with high-risk, operable breast carcinoma. Ann Surg Oncol. 2006 May;13(5):677-84. PMID: 16538409. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
105 | Pusztai L, Wagner P, Ibrahim N, et al. Phase II study of tariquidar, a selective P-glycoprotein inhibitor, in patients with chemotherapy-resistant, advanced breast carcinoma. Cancer. 2005 Aug 15;104(4):682-91. PMID: 15986399. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
106 | Qamri Z, Preet A, Nasser MW, et al. Synthetic cannabinoid receptor agonists inhibit tumor growth and metastasis of breast cancer. Mol Cancer Ther. 2009 Nov;8(11):3117-29. PMID: 19887554. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
107 | Rades D, Douglas S, Veninga T, et al. Prognostic factors in a series of 504 breast cancer patients with metastatic spinal cord compression. Strahlenther Onkol. 2012 Apr;188(4):340-5. PMID: 22354333. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
108 | Rebollo-Aguirre AC, Gallego-Peinado M, Menjon-Beltran S, et al. Sentinel lymph node biopsy in patients with operable breast cancer treated with neoadjuvant chemotherapy. Rev Esp Med Nucl Imagen Mol. 2012 May-Jun;31(3):117-23. PMID: 21676504. | Article did not include metastatic breast cancer patients.
109 | Rimner A, Rosenzweig KE. Palliative radiation for lung cancer metastases to the breast: two case reports. J Thorac Oncol. 2007 Dec;2(12):1133-5. PMID: 18090590. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
110 | Roddiger SJ, Kolotas C, Filipowicz I, et al. Neoadjuvant interstitial high-dose-rate (HDR) brachytherapy combined with systemic chemotherapy in patients with breast cancer. Strahlenther Onkol. 2006 Jan;182(1):22-9. PMID: 16404517. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
111 | Roos DE, Brophy BP, Taylor J. Lessons from a 17-year radiosurgery experience at the Royal Adelaide Hospital. Int J Radiat Oncol Biol Phys. 2012 Jan 1;82(1):102-6. PMID: 21036488. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
112 | Rousseau C, Devillers A, Campone M, et al. FDG PET evaluation of early axillary lymph node response to neoadjuvant chemotherapy in stage II and III breast cancer patients. Eur J Nucl Med Mol Imaging. 2011 Jun;38(6):1029-36. PMID: 21308372. | Article did not include metastatic breast cancer patients.
113 | Ruhl R, Ludemann L, Czarnecka A, et al. Radiobiological restrictions and tolerance doses of repeated single-fraction hdr-irradiation of intersecting small liver volumes for recurrent hepatic metastases. Radiat Oncol. 2010;5:44. PMID: 20507615. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
114 | Ruhstaller T, von Moos R, Rufibach K, et al. Breast cancer patients on endocrine therapy reveal more symptoms when self-reporting than in pivotal trials: an outcome research study. Oncology. 2009;76(2):142-8. PMID: 19158446. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
115 | Saito AI, Lightsey J, Li JG, et al. Accuracy of breast cancer axillary lymph node treatment plans based on 2-dimensional imaging: what we should know before interpreting 2-dimensional treatment-planning era studies. Am J Clin Oncol. 2009 Aug;32(4):387-95. PMID: 19546802. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
116 | Salloum RG, Hornbrook MC, Fishman PA, et al. Adherence to surveillance care guidelines after breast and colorectal cancer treatment with curative intent. Cancer. 2012 Nov 15;118(22):5644-51. PMID: 22434568. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
117 | Sato K, Shigenaga R, Ueda S, et al. Sentinel lymph node biopsy for breast cancer. J Surg Oncol. 2007 Sep 15;96(4):322-9. PMID: 17879334. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
118 | Seemann MD. Diagnostic value of PET/CT for predicting of neoadjuvant chemotherapy response. Eur J Med Res. 2007 Feb 26;12(2):90-1. PMID: 17369123. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
119 | Servais EL, Colovos C, Kachala SS, et al. Pre-clinical mouse models of primary and metastatic pleural cancers of the lung and breast and the use of bioluminescent imaging to monitor pleural tumor burden. Curr Protoc Pharmacol. 2011 Sep;Chapter 14:Unit14.21. PMID: 21898334. | Non-human study.
120 | Sethi RA, No HS, Jozsef G, et al. Comparison of three-dimensional versus intensity-modulated radiotherapy techniques to treat breast and axillary level III and supraclavicular nodes in a prone versus supine position. Radiother Oncol. 2012 Jan;102(1):74-81. PMID: 21993404. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
121 | Souchon R, Wenz F, Sedlmayer F, et al. DEGRO practice guidelines for palliative radiotherapy of metastatic breast cancer: bone metastases and metastatic spinal cord compression (MSCC). Strahlenther Onkol. 2009 Jul;185(7):417-24. PMID: 19714302. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
122 | Spear SL, Clemens MW, Dayan JH. Considerations of previous augmentation in subsequent breast reconstruction. Aesthet Surg J. 2008 May-Jun;28(3):285-93. PMID: 19083539. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
123 | Sperber F, Weinstein Y, Sarid D, et al. Preoperative clinical, mammographic and sonographic assessment of neoadjuvant chemotherapy response in breast cancer. Isr Med Assoc J. 2006 May;8(5):342-6. PMID: 16805235. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
124 | Stranzl H, Zurl B, Langsenlehner T, et al. Wide tangential fields including the internal mammary lymph nodes in patients with left-sided breast cancer. Influence of respiratory-controlled radiotherapy (4D-CT) on cardiac exposure. Strahlenther Onkol. 2009 Mar;185(3):155-60. PMID: 19330291. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
125 | Straver ME, Loo CE, Alderliesten T, et al. Marking the axilla with radioactive iodine seeds (MARI procedure) may reduce the need for axillary dissection after neoadjuvant chemotherapy for breast cancer. Br J Surg. 2010 Aug;97(8):1226-31. PMID: 20602508. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
126 | Sun G, Jin P, Li M, et al. Percutaneous vertebroplasty for treatment of osteolytic metastases of the C2 vertebral body using anterolateral and posterolateral approach. Technol Cancer Res Treat. 2010 Aug;9(4):417-22. PMID: 20626207. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
127 | Tisman G. Inhibition of HER2/estrogen receptor cross-talk, probable relation to prolonged remission of stage IV breast cancer: a case report. Tumori. 2009 Nov-Dec;95(6):804-7. PMID: 20210247. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
128 | Tolentino PJ. Brain metastases secondary to breast cancer: treatment with surgical resection and stereotactic radiosurgery. Mo Med. 2009 Nov-Dec;106(6):428-31. PMID: 20063515. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
129 | Tomasevic ZI, Rakocevic Z, Tomasevic ZM, et al. Incidence of brain metastases in early stage HER2 3+ breast cancer patients; is there a role for brain CT in asymptomatic patients? J buon. 2012 Apr-Jun;17(2):249-53. PMID: 22740201. | Article addressed diagnosing brain metastases, not evaluating treatment of metastatic breast cancer
130 | Trumm CG, Jakobs TF, Zech CJ, et al. CT fluoroscopy-guided percutaneous vertebroplasty for the treatment of osteolytic breast cancer metastases: results in 62 sessions with 86 vertebrae treated. J Vasc Interv Radiol. 2008 Nov;19(11):1596-606. PMID: 18954766. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
131 | Tsai SH, Chen CY, Ku CH, et al. The semiquantitative bone scintigraphy index correlates with serum tartrate-resistant acid phosphatase activity in breast cancer patients with bone metastasis. Mayo Clin Proc. 2007 Aug;82(8):917-26. PMID: 17673059. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
132 | Wallace AM, Comstock C, Hoh CK, et al. Breast imaging: a surgeon's prospective. Nucl Med Biol. 2005 Oct;32(7):781-92. PMID: 16243654. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
133 | Wang X, Zhang W, Xu Z, et al. Sonodynamic and photodynamic therapy in advanced breast carcinoma: a report of 3 cases. Integr Cancer Ther. 2009 Sep;8(3):283-7. PMID: 19815599. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
134 | Wang X, Zhao Y, Cao X. Clinical benefits of mastectomy on treatment of occult breast carcinoma presenting axillary metastases. Breast J. 2010 Jan-Feb;16(1):32-7. PMID: 20465598. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
135 | Wieners G, Mohnike K, Peters N, et al. Treatment of hepatic metastases of breast cancer with CT-guided interstitial brachytherapy - a phase II-study. Radiother Oncol. 2011 Aug;100(2):314-9. PMID: 21497930. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
136 | Wiggenraad R, Verbeek-de Kanter A, Mast M, et al. Local progression and pseudo progression after single fraction or fractionated stereotactic radiotherapy for large brain metastases. A single centre study. Strahlenther Onkol. 2012 Aug;188(8):696-701. PMID: 22722818. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
137 | Wilbert J, Guckenberger M, Polat B, et al. Semi-robotic 6 degree of freedom positioning for intracranial high precision radiotherapy; first phantom and clinical results. Radiat Oncol. 2010;5:42. PMID: 20504338. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
138 | Wiseman CL, Kharazi A. Objective clinical regression of metastatic breast cancer in disparate sites after use of whole-cell vaccine genetically modified to release sargramostim. Breast J. 2006 Sep-Oct;12(5):475-80. PMID: 16958969. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
139 | Yasojima H, Shimomura A, Naoi Y, et al. Association between c-myc amplification and pathological complete response to neoadjuvant chemotherapy in breast cancer. Eur J Cancer. 2011 Aug;47(12):1779-88. PMID: 21741827. | Article did not include metastatic breast cancer patients.
140 | Yavetz D, Corn BW, Matceyevsky D, et al. Improved treatment of the breast and supraclavicular fossa based on a simple geometrical principle. Med Dosim. 2011 Winter;36(4):434-9. PMID: 21397491. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
141 | Yen CP, Sheehan J, Patterson G, et al. Gamma knife surgery for metastatic brainstem tumors. J Neurosurg. 2006 Aug;105(2):213-9. PMID: 17219825. | Article did not address use of imaging for treatment evaluation for metastatic breast cancer.
142 | Yu JC, Hsu GC, Hsieh CB, et al. Role of sentinel lymphadenectomy combined with intraoperative ultrasound in the assessment of locally advanced breast cancer after neoadjuvant chemotherapy. Ann Surg Oncol. 2007 Jan;14(1):174-80. PMID: 17066228. | Article did not include metastatic breast cancer patients.