# List of Abstracted Published Literature Studies

Number | Citation
1 | Buijs M, Kamel IR, Vossen JA, et al. Assessment of metastatic breast cancer response to chemoembolization with contrast agent enhanced and diffusion-weighted MR imaging. J Vasc Interv Radiol. 18(8):957-63, 2007 Aug. PMID: 17675611.
2 | Cachin F, Prince HM, Hogg A, et al. Powerful prognostic stratification by [18F]fluorodeoxyglucose positron emission tomography in patients with metastatic breast cancer treated with high-dose chemotherapy. J Clin Oncol. 24(19):3026-31, 2006 Jul 1. PMID: 16717291.
3 | Cheng J, Lei L., Xu J, et al. 18F-fluoromisonidazole PET/CT: a potential tool for predicting primary endocrine therapy resistance in breast cancer. J Nucl Med. 54(3):333-40, 2013 Mar. PMID: 23401605.
4 | Contractor KB, Kenny LM, Stebbing J, et al. [18F]-3'Deoxy-3'-fluorothymidine positron emission tomography and breast cancer response to docetaxel. Clin Cancer Res. 17(24):7664-72, 2011 Dec 15. PMID: 22028493.
5 | Contractor K, Aboagye EO, Jacob J, et al. Monitoring early response to taxane therapy in advanced breast cancer with circulating tumor cells and [(18)F] 3`-deoxy-3`-fluorothymidine PET: a pilot study. Biomark Med. 6(2):231-3, 2012 Apr. PMID: 22448798 .
6 | De Giorgi U, Valero V, Rohren E, et al. Fritsche HA. Macapinlac HA. Hortobagyi GN. Cristofanilli M. Circulating tumor cells and [18F]fluorodeoxyglucose positron emission tomography/computed tomography for outcome prediction in metastatic breast cancer. J Clin Oncol 27 (20) 3303-11, 2009. PMID: 19451443.
7 | Dose Schwarz J, Bader M, Jenicke L, et al. Early prediction of response to chemotherapy in metastatic breast cancer using sequential 18F-FDG PET. J Nucl Med. 46(7):1144-50, 2005 Jul. PMID: 16000283.
8 | Haug AR, Tiega Donfack BP, Trumm C., et al. Bartenstein P. Heinemann V. Hacker M. 18F-FDG PET/CT predicts survival after radioembolization of hepatic metastases from breast cancer. J Nucl Med. 53(3):371-7, 2012 Mar. PMID: 22331219.
9 | Huyge V, Garcia C, Alexiou J, eet al. Heterogeneity of metabolic response to systemic therapy in metastatic breast cancer patients. Clin Oncol (R Coll Radiol). 22(10):818-27, 2010 Dec. PMID: 20554438.
10 | Kenny L, Coombes RC, Vigushin DM, et al. Imaging early changes in proliferation at 1 week post chemotherapy: a pilot study in breast cancer patients with 3'-deoxy-3'-[18F]fluorothymidine positron emission tomography. Eur J Nucl Med Mol Imaging. 34(9):1339-47, 2007 Sep. PMID: 17333178.
11 | Linden HM, Stekhova SA, Link JM, et al. Quantitative fluoroestradiol positron emission tomography imaging predicts response to endocrine treatment in breast cancer. J Clin Oncol. 24(18):2793-9, 2006 Jun 20. PMID: 16682724.
12 | Linden HM, Kurland BF, Peterson LM, et al. Fluoroestradiol positron emission tomography reveals differences in pharmacodynamics of aromatase inhibitors, tamoxifen, and fulvestrant in patients with metastatic breast cancer. Clin Cancer Res. 17(14):4799-805, 2011 Jul 15. PMID: 21750198.
13 | Mortazavi-Jehanno N, Giraudet AL, Champion L et al. Assessment of response to endocrine therapy using FDG PET/CT in metastatic breast cancer: a pilot study. Eur J Nucl Med Mol Imaging. 39(3):450-60, 2012 Mar. PMID: 22183107.
14 | Pio BS, Park CK, Pietras R, et al. Usefulness of 3'-[F-18]fluoro-3'-deoxythymidine with positron emission tomography in predicting breast cancer response to therapy. Mol Imaging Biol 8 (1) 36-42, 2006. PMID: 16362149.
15 | Specht JM, Tam SL, Kurland BF, et al. Serial 2-[18F] fluoro-2-deoxy-D-glucose positron emission tomography (FDG-PET) to monitor treatment of bone-dominant metastatic breast cancer predicts time to progression (TTP). Breast Cancer Res Treat 105 (1) 2007. PMID: 17268819.
16 | Tateishi U, Gamez C, Dawood S, et al. Bone metastases in patients with metastatic breast cancer: morphologic and metabolic monitoring of response to systemic therapy with integrated PET/CT. Radiology. 247, 2008. PMID: 18372468.
17 | Hayashi N, Costelloe CM, Hamaoka T, et al. A prospective study of bone tumor response assessment in metastatic breast cancer. Clin Breast Cancer. 2013 Feb;13(1):24-30. PMID: 23098575.